# Use of Simulation Exercises in Patient Safety Efforts

## How Important Is the Problem?

Every July, patients are treated by new residents and fellows who have started their training programs only days before. Given that error rates drop with experience,1-4 an important challenge is how to train physicians while minimizing the potential for patient harm. Many medical educators now regard the traditional medical training model “See one, Do one, Teach one,” as unstructured and inadequate.5,6 For example, before performing a procedure like airway intubation on a patient for the first time, a trainee likely would have read about the theory with some visuals, but may or may not have touched the equipment, discussed the detailed steps and common pitfalls, or necessarily observed an experienced physician performing the procedure. Before being a team leader, for example before coordinating a cardiac arrest resuscitation, a senior resident would likely have participated in prior resuscitations but may never have formally debriefed the experience to learn from it. However, simulation exercises or drills allow residents and trainees to practice the necessary steps in a safe situation. Then, a debrief is often structured with dedicated time to reflect upon what worked well and what did not during the exercise to identify ways to improve the next resuscitation. Without such simulations, the team leader would by definition never have practiced being the leader before “going live” in this role for the first time. While all physicians still must perform procedures on and manage critical events for an actual patient for the first time, simulation is likely to make this first time safer and more efficient.

However, the use of patient safety efforts that involve simulation target not just inexperience. Clinical expertise and mastery within a specialty does not increase simply as a function of experience,7,8 and, likewise, patient safety issues are not likely to decrease simply as a function of more practice hours: experienced surgeons are involved in a notable proportion of malpractice claims.9 Simulation with debriefing, or other forms of “deliberate practice” and reflection are needed to continuously improve care. With experience, comes increased pressure in supervising roles and increased clinical demand to treat the most complex, difficult, and rare conditions. The likelihood of desirable outcomes can be increased, even among experienced clinicians, as simulation allows adjustment of the complexity of the procedures and regular practice with treatment for rare conditions. At times, the most senior clinicians will be called on to perform tasks outside of their specialty due to medical necessity or availability of resources (e.g., in rural areas). Simulation may provide a mechanism for clinicians to practice responding to these high-stakes situations without harm to patients. In addition to developing these “advanced” techniques, experienced clinicians must maintain proficiency in a wide array of skills, some of which are known to deteriorate over time without practice.10,11 Simulation can serve to maintain clinical skills and may be part of maintenance of board certification, as is the case for The American Board of Anesthesiology.12

Simulation can also address team and organizational issues that challenge patient safety. Technical errors may occur in a team care environment as a result of nontechnical factors (e.g., communication), and specific simulation-based training protocols have been developed for enhancing team performance. These protocols include Anesthesiology Crisis Resource Management.13 Likewise, simulation may provide a way to assess the efficiency and safety of system-level practices that may be difficult to control in real time or unsafe to test empirically.

Simulation has received increased recognition since the release of “Making Health Care Safer” and seminal Institute of Medicine reports on preventable medical errors and mortality.14,15 The Agency for Healthcare Research and Quality (AHRQ) continues to fund a number of projects dedicated to enhancing patient safety through simulation.16,17 Accrediting bodies from the American Association of College of Nurses, American College of Surgeons, American Association of Anesthesiologists, and Society for Simulation in Healthcare have all supported simulation training centers.18-20

Studies evaluating the relationship between the benefits of simulation exercises and patient safety outcomes, including potential harms, have not been thoroughly evaluated. Therefore, the purpose of this chapter is to systematically review evidence on the benefits and harms of using simulation to improve patient safety in medicine.

## What Is the Patient Safety Practice?

The use of simulation has a long history in health services education.21-23 However, recent advances in simulation have been inspired by aviation and other high-reliability, high-stakes industries that emphasized the inherent value of allowing initial practice of all crucial skills during simulation, as a lower-stakes context, but with sufficient realism for the skills to transfer effectively. In the 1990s, Gaba and Howard developed simulation courses for Anesthesia Crisis Resource Management built upon Crew Resource Management (CRM) principles from aviation (see the chapter “Team-Training in Healthcare: Brief Review” for more information on CRM in health care).13 In addition to enhancing team performance, use of simulations to improve understanding of technological advances and effective practices among individuals and care systems has increased substantially in the past decade.

Simulation is considered a technique rather than any one patient safety practice. Importantly, this technique is versatile as it may be applied across specialties and levels of intervention.24 Simulation to enhance patient safety has four general purposes25 :

1. Education
2. Assessment
3. Research
4. Health System Integration

These purposes are not mutually exclusive, and each may span a range of complexity. Simulation serves an educational role in transitioning trainees from content knowledge to experiential practice, in continuing education, and in moving toward advanced practices. A classic low-fidelity example is training intramuscular medication administration through simulated practice inserting a needle into an orange. More complicated “partial task training” may now include high-fidelity simulations that utilize anatomically accurate mannequins with realistic surgical equipment monitored by computer. Patient safety may also be enhanced through “full scenario management,” a fully-simulated care environment such as entire operating rooms and care teams. In addition to educational aims, simulators can provide structure for critical assessment in quality control or quality improvement through systematic research into clinician behaviors, care team processes, and integrating health system-level processes. Simulation is particularly useful for research into processes that cannot be varied in a study without undue harm to patients. Specific considerations in implementing simulation are detailed in a later section of this chapter.

On a basic level, simulations improve patient safety by allowing physicians to become better trained without putting patients at risk and, importantly, by providing a protected time for reflection and debriefing. The challenge is matching the best simulation method and training details for the desired learning objectives, while recognizing the costs of each method.24 Because simulation is a broad technique, rather than a specific technology, faculty training and time are often considered a more important investment than are specific expensive simulation equipment. Given that most clinicians are not trained in simulation and debriefing, specific practitioners with interest in the area must be appropriately trained to effectively use simulation techniques, as well as any specific desired technologies, in order to accomplish the relevant training or systems probing goals. The significant investment of time requires that faculty are provided time to develop and teach meaningful simulations. Besides some procedural skills that may require mainly repetitive practice, most simulations require an extensive debriefing component, during which much of the learning takes place. Learning to effectively facilitate debriefings is often the most time-intensive component of faculty training.26,27

The simulation itself needs to feel real enough for participants to be able to “suspend disbelief,” acting and thinking much as they would in a similar but real scenario.25 If the learning objective is mainly to practice cognitive skills for diagnosis or treatment, a verbal simulation such as “What would you do if…” may be sufficient. In contrast, if time pressure and/or team communication are the focus, a more accurate replication of the actions and team presence become important for the simulation experience.

## Why Should This Patient Safety Practice Work?

Research demonstrating the benefits of simulation comes from studies about simulation as well as studies using simulation.28 Research about simulation directly examines the effect of a simulation technique as an intervention on behaviors and actions at the health professional or team level that could directly improve patient safety if that training were widely implemented. Studies using simulation harness these techniques as a laboratory to investigate new technologies and human performance for insights into potential causal pathways to improve safety. Strategies that employ simulation techniques may do so as part of a multicomponent intervention or may focus on the simulation alone. The versatility of simulation techniques affords those working to improve patient safety a number of benefits.

First, simulation is initiated on command and may be practiced repeatedly. Additionally, the content of simulated exercises may be structured to meet particular goals. Thus simulation has been utilized to enhance the reliability of clinician behaviors in order to reduce medical error associated with inexperience or undesirable levels of competency.1-4 A systematic review of simulation with deliberate practice added to traditional training models reported in favor of simulation for enhancing clinicians' technical skills performance (pooled effect size = 0.71, 95% CI, 0.65 to 0.76, p < .001).29 Simulation has been associated with improved knowledge acquisition and clinical reasoning beyond traditional training in other studies as well,30 and one meta-analysis reported that training with computerized virtual patients enhanced performance in actual patient care (pooled effect size = 0.50; 95% CI, 0.34 to 1.19).31 The nature of simulation also allows practitioners experience with rare and unpredictable care scenarios (e.g., mass casualty incidents),32 with rare clinical events, and with advancing to mastery levels in a specialty.7,8

Second, simulation may be particularly valuable in duplicating complex high-stakes scenarios that involve care teams and complex factors that affect performance.33,34 During an Anesthesiology Crisis Resource Management simulation (including realistic emergency scenarios, team communication, and complex decisionmaking), Blum and colleagues planted “probes” of clinically pertinent information known only to a single member of the care team.35 These researchers found that participants shared only 27 percent of the probes with the team, electing instead to share redundant information already available to others. Authority and power differentials between senior and junior clinicians may also hinder effective communication, and reluctance to challenge superiors may result in medical errors in high-stakes scenarios. The field of aviation uses a method called the two-challenge rule to train all team members in a technique known as advocacy-inquiry, giving junior team members the language to “speak up” while seeking clarification. To study use of the two-challenge concept in debriefing anesthesiology trainees, Pian-Smith and colleagues structured emergency simulations with contraindicated decisions made by attending clinicians.36 The researchers discovered that trainees were initially reluctant to challenge their superiors, but after debriefing, they were significantly more likely to make an effective and clear challenge to contraindicated decisions by attending clinicians.

Third, errors are allowed in simulation and utilized as learning experiences through reflection and debriefing. Training with real patients requires that supervising clinicians intervene if certain errors occur, disallowing trainees to carry out the remainder of the procedure or to protect time for debriefing. Additionally, as Fanning and colleagues note, reflective practices are considered a cornerstone of life-long education in medicine.26 Simulation may facilitate highly accurate measures of specific care-related behaviors and processes (technical or non-technical) for the purpose of debriefing and reflection.26,27 Debriefing has exerted an increased performance effect over self-study in high-fidelity simulated assessments.37

Fourth, simulation may be used to test new technologies, especially complex ones that involve new learning curves in even the most experienced of clinicians.38 Likewise, new team processes or innovative practices may be simulated prior to implementing in real time.39 Simulation may also help resolve disputes between best care practices. For example, cardiopulmonary arrest of a woman pregnant for greater than 20 weeks requires cesarean delivery within 5 minutes of onset, to protect both mother and fetus. However, debate has existed as to whether the procedure should be performed in the labor room or in an operating room after transporting the patient. Clearly, one would not consider placing actual patients in harm's way just for the purpose of settling this debate in research. However, utilizing simulation in a randomized design, Lipman and colleagues determined that the average time to incision was three and half minutes longer in teams instructed to transport patients to the operating room.40

Lastly, teams can simulate patient care flow in situ, for critical events41-43 as well as new facility “usual care,” to check for the proper equipment (e.g., severe hemorrhage drills on various hospital units or new operating rooms, respectively).44,45 Researchers have utilized simulation-based communication training to enhance inter-agency processes such as telephone referrals,46 but this use remains a relatively under-studied area.

## What Are the Beneficial Effects of the Patient Safety Practice?

Questions regarding the details of a simulation intervention and its measurable impact on patient outcomes are difficult to answer for many reasons, so there have been relatively few studies in this arena. The measurable outcome may vary substantially based on the specific behavior or process under investigation. For example, small gains may be expected on patient outcomes from additional simulation exercises when assessing clinicians who must first demonstrate a minimum acceptable level of competency before practicing on actual patients. Likewise, comparing experienced to expert clinicians requires a highly sensitive and specific methodology that is still being developed currently among simulation experts.7,8 A plethora of simulation research has been conducted on what translational science refers to as T1, or “laboratory-only,” outcomes.12,47 As noted above, T1 studies, or research about simulation, support the logic for why simulation matters for patient safety. This section on beneficial effects of simulation focuses on studies that reported T2 or T3 outcomes and that were published since “Making Health Care Safer,” or those studies that translate interventions directly to patient-level and systems-level outcomes, respectively.12,47 Studies are grouped into simulation exercises that assessed patient outcomes related to practitioner technical performance, team-level, and system-level outcomes. Following these sections is an in-depth review of literature on patient outcomes related to central venous catheterization.

### Practitioner Performance

This section focuses on the technical aspects of physician performance during procedures. Although technical skills are a crucial component to effective and safe health care, there is potential for simulation to improve cognitive and other decision-making processes that impact the delivery of services.

Diagnostic procedures. In a randomized trial with first-year gastroenterology fellows, simulation-trained fellows out-performed traditionally-trained fellows during standardized assessment of performance on the first 80 colonoscopy procedures (p = 0.03). The difference between groups did not persist beyond 80 procedures, and the researchers determined that both groups required the entire 200-colonoscopy training experience to achieve a desirable level of procedure mastery.48 Another randomized study of first-year gastroenterology fellows reported similar results, with simulation-trained clinicians successfully reaching the cecum in 38 percent of their first 15 colonoscopies compared with 20 percent in the control group (p = 0.027). Differences between groups were also observable through 30 procedures, but differences did not persist beyond 30 procedures.49 Other studies have reported earlier acquisition and higher performance in first colonoscopies performed among trainees who received simulation training,50-52 and one reported that simulation-trained clinicians reached the cecum 4.5 times more often on average than did clinicians in the control group during their first 10 procedures (95% CI, 1.89 to 11.60, p = 0.001).50 Similar effects of simulation on increased early performance enhancement, and, subsequently, absence of differences between study groups, were reported for upper gastrointestinal endoscopy.53 In a randomized study, bronchoscopy simulation exerted no effect on procedure time.54 Safety outcomes reported in these studies focused primarily on patient discomfort (e.g., insufflation), and simulation training was associated with lower discomfort in one study,50 no difference in another,48 and higher patient discomfort in a third.49

In a before and after design, thoracenteses performed after implementing simulation in a training curriculum involved fewer pneumothoraces (8.7% before vs. 1.1% after, p = 0.003) and procedures advancing to thoracostomy (6% before vs. 0% after, p = 0.003) than those performed prior to simulation-based training.55 In a similar type of research design examining cordocentesis, procedure time was lower (6.4 min vs. 13.2 min, p < 0.001) and success rate was higher (98.8% vs. 94.8%, p < 0.001) after implementing simulation training. There was no difference between the before- and after-simulation study periods in procedure-related fetal loss or overall fetal loss.56

Surgical procedures. A meta-analysis of laparoscopic training with virtual reality simulators reported that procedure time was no faster, but was more accurate (standardized mean difference [SMD] 0.68, 95% CI 0.05 – 1.31) in simulation-trained clinicians compared with traditional video-trained clinicians. These authors reported no difference between simulation-trained and other-trained clinicians in conversion rate to open surgery.57 Surgical residents who were randomized to simulation training on laparoscopic cholecystectomy exhibited fewer errors in exposing (control mean = 53.4, simulator mean = 15.0, p < 0.04), clipping (control mean = 7.1, simulator mean = 1.9, p < 0.008), and dissection (control mean = 29.5, simulator mean = 11.5, p < 0.03) during their first ten cholecystectomies. Three-fold fewer total errors and an eight-fold decreased variation in error making totals were found among simulation-trained clinicians.58 Another study reported that “warming up” with laparoscopic simulation led to increased observed structured assessment of technical skills (OSATS) global rating on actual cholecystectomies in trainee- and experienced clinicians (warm-up mean = 28.50, control mean = 19.25, p = 0.042), but no significant differences were reported on any one technical skill.59 Compared with no simulation training among surgery residents, simulation training for extraperitoneal hernia repair was associated with larger increases in OSATS scores over a baseline procedure for knowledge of procedure (p < 0.05), knowledge of instruments (p = 0.05), and use of assistants (p < 0.05), but not global score.60 Researchers have utilized simulation for other surgical modalities as well. In one study, urology residents trained with simulators performed prostate resection faster (p = 0.025), and with higher performance scores on a structured assessment (p = 0.021) than those not trained with simulation.61

Other procedures and processes. Pediatrics interns (n = 38) were randomized to simulation training on basic procedural skills or training as usual for bag-mask ventilation, venipuncture, peripheral venous catheter placement, and lumbar puncture. Interns in the simulation group exhibited a higher, but not significantly higher, rate of successful venipuncture (p = 0.08). No significant differences were observed between groups on the other procedural skills, although performance scores on all measures were higher in the simulation group.62 Simulation has shown additional benefits over traditional training in other areas of patient safety. Bachelor's level nursing students randomized to traditional pharmacology coursework or coursework with additional simulation training were observed for medication administration errors in subsequent external training placements. Students who trained with simulation made fewer medication administration errors (7 of 31 total errors observed, p < 0.05), and these results were consistent across both maternal health (control group = 8 errors, simulation group = 0 errors) and medical-surgical settings (control group = 16 errors, simulation group = 7 errors).63 In another study, paramedic students who received simulation training for endotracheal intubation performed similarly to traditionally-trained students on their first 15 intubations for overall success rate, success rate on first attempt, and in complications resulting from the intubation procedure.64

Although central venous cathether (CVC) placement is a specific procedure, the in-depth review of literature on CVC is reviewed below. Again, the physician is not only a technician but an actor that must balance being cognitively engaged with direct patient care as well as the system within which she or he works. These systems include interpersonal dynamics such as dyadic relationships (e.g., doctor-nurse pairs), larger team relationships (e.g., cardiac resuscitation), and the care culture and environment (e.g., patient safety culture, and available resources). Simulation has the potential to impact care processes and relationships at each of these levels.

### Team and Systems Performance

A 1-day workshop and training program implemented simulation for seven common obstetric emergencies in the third year of a 6-year study period: shoulder dystocia, postpartum hemorrhage, eclampsia, delivery of twins, breech, adult resuscitation, and neonatal resuscitation. The researchers compared live-term births in the period prior to simulation (n = 8,430) to live-term births after implementing simulation (n = 11,030) into the training workshop. Births with 5-minute APGAR less than or equal to 6 decreased from 73/10,000 births (SD = 86.6) pre-simulation to 49/10,000 births (SD = 44.4) after implementing simulation training (p < 0.05). The rate of hypoxic-ischemic encephalopathy also decreased from 23/10,000 births (SD = 27.3) to 15/10,000 (SD = 13.6, p <0 .05). The rate of moderate to severe hypoxic-ischemic encephalopathy decreased, but not significantly.65

Primary care physicians (n = 51) in a large, multidisciplinary medical group were randomized to simulation training alone, simulation training with physician-leader feedback, or a control group. Medical records were evaluated for metformin prescriptions to patients with diabetes who had regularly attended care for two years (n = 2,020) and that had either known congestive heart failure or a laboratory result with elevated creatinine. The rate at which control-group physicians prescribed renal-contraindicated metformin was not statistically different compared with either simulation group alone. However, when simulation groups were combined, the simulation-trained physicians prescribed metformin in these unsafe scenarios significantly less often (range from -3.8 to -10.3% across simulation groups, p = 0.03).66

Year-four postgraduate anesthesiology residents (n = 20) were randomized to a full mission-type simulation for patients weaning from cardiopulmonary bypass that included a complete operating room environment and care team. Residents were scored during actual performance in elective coronary artery bypass graft (CABG) with a structured anesthesiologist's nontechnical skills (ANTS) assessment before and after the simulation. The simulation-trained grouped exhibited significantly increased scores after the simulation training over the increases realized in the control group (control mean = 11.8, simulation mean = 14.3, p < 0.001) and at 5-week followup (control mean = 11.7, simulation mean = 14.1, p < 0.001).67

Two studies reported patient outcomes after simulation-based training for resuscitation teams. In one study, internal medicine residents were trained in team management for resuscitation scenarios. These authors reported no differences attributable to simulation training for actual team performance on ventilation rate, return of spontaneous blood circulation, or survival to discharge rates. Of note, both of the latter rates were higher in the simulation group.68 However, another study examined resuscitation outcomes after implementing the TeamSTEPPS team-building program coupled with simulation. This study reported a number of significant communication improvements during observed resuscitations, such as leadership (p = 0.003), situation monitoring (p = 0.009), mutual support (p = 0.004), and communication (p = 0.001). Post-simulation reductions were also noted in average time to computed tomography (26.4 min vs. 22.1 min, p = 0.005), to intubation (10.1 min vs. 6.6 min, p = 0.49), and to operating room (130.1 min vs. 94.5 min, p = 0.021).69 A team-response and educational curriculum coupled with debriefing was provided to second-year internal medicine residents (n = 38) whose performance on subsequent resuscitations was compared with third-year residents (n = 40) who did not receive simulation training. Based on American Heart Association standards, simulation-trained residents made 68 percent correct responses compared with 44 percent in the non-simulation-trained residents (mean difference = 44%, p < 0.001).41

### In-Depth Look at Simulation and Central Venous Catheterization

Central venous catheters (CVC) are used to obtain vascular access as well as hemodynamic monitoring and are common fixtures in ICU settings. In fact, 48 percent of patients in the ICU have indwelling CVC, which corresponds to 15 million CVC patient days per year.70,71 Despite the broad presence of CVC in the ICU, significant morbidity and mortality are associated with CVC.71,72 Although catheter-related blood stream infections (CRBSI) have been studied extensively, and a separate companion evidence report is dedicated to Heathcare Associated Infections, simulation promises to exert protective effects against risks involved with the insertion process, including pneumothorax, arterial puncture, bleeding, and deep vein thrombosis.73 Due to these risks, Federal agencies such as the National Quality Forum and AHRQ have listed CVC practices as a top patient safety concern.74,75

Trainees in internal medicine, emergency medicine, and surgical specialties commonly insert CVC in academic settings.76 Despite requirements to demonstrate knowledge about indications, contraindications, complications, and sterile technique for CVC insertions,77,78 trainees remain uncomfortable with performing the procedure.79 Training had previously consisted of the apprenticeship model with learning at bedside on actual patients; however, this method is often found to be inadequate.41,80 A recent meta-analysis has shown that simulation-based education in CVC techniques improves both learner outcomes and performance during actual procedures: fewer needle passes (standardized mean difference = -0.58, 95% CI -0.95 to -0.20) and reduced pneumothoraces (relative risk = 0.62, 95% CI 0.40 to 0.97).81

In addition to the articles included in this meta-analysis, studies have demonstrated that simulation improves learner outcomes such as knowledge, confidence, and performance on simulators as well patient outcomes such as fewer needle passes, fewer pneumothoraces, and less CRBSI (Table 1 below). These studies may not be direct replication of each other, but the consistency in observed benefits of simulation across a variety of clinical specialties and care settings is promising. Additionally, these studies have been conducted across numerous research teams in academic or teaching hospitals. Many of these studies used a high-fidelity mannequin partial-task trainer on CVC insertion. However, more involved simulations include sanitation techniques and incorporate the entirety of the operation rather than any specific operative technique. Additionally, once operational, these simulators have been utilized for differing patient needs such as for pediatric medicine instead of adult medicine as well as other types of CVC, including hemodialysis catheters.82,83 Future and ongoing investigations will give us further insight into long term maintenance of CVC skills with simulation.84

Table 1, Chapter 38 Literature on simulation training for central venous catheterization

Study | Study Design | Patient Safety Simulation Practice | Simulation Participants | Setting, Results, and Patient-Related Outcomes
Andreatta et al. (2011)93 | Randomized controlled, blinded, trial | One hour minimum practice time with high-fidelity partial task trainer and ultrasound system, with supervision and individualized training program | PGY-1 and PGY-2 radiology residents (n = 32) performed 32 peripherally inserted central catheters | In interventional radiology at a single academic health system, simulator-trained residents outperformed bedside-trained residence on a number of performance criteria such as ultrasound use, vein compressibility, needle localization and guiding, and exchanging the needle/catheter via the guidewire (p < 0.05 for all). All simulator-trained residents placed the catheter successfully, whereas 4 of 16 bedside-trained residents were unable to place the catheter independently within three attempts.
Barsuk et al. (2009)88 | Non-randomized observational cohort with historical cohort for controls | Minimum proficiency/mastery model on standardized checklist of CVC insertion with expert panel review of performance using a high-fidelity partial task trainer with computer interface, simulation exercises performed with deliberate practice and individualized feedback components | PGY-2 and PGY-3 internal medicine and emergency medicine residents (n = 103) performed 407 internal jugular and subclavian CVCs | In the medical ICU of a single academic institution, there were no significant differences in the outcomes of subclavian line insertion; however, residents who were simulator trained reported fewer needle passes (p < 0.0005), arterial punctures (p < 0.0005), catheter adjustments (p = 0.002), and higher success rate (p = 0.005) in overall central venous catheter placement.
Barsuk et al. (2009)76 | Pre-post, non-randomized observational cohort | Minimum proficiency/mastery model on standardized checklist of CVC insertion with expert panel review of performance using a high-fidelity partial task trainer with computer interface, simulation exercises performed with deliberate practice and individualized feedback components | PGY-2 and PGY-3 internal medicine and emergency medicine residents (n = 92), number of CVCs performed NR | In the medical ICU of a single academic institution, fewer CRBSI occurred after simulation, and the rate of CRBSI after simulation training reduced from 3.2 per 1000 catheter-days to 0.5 per 1000 catheter-days (p = 0.001). Comparing the medical (MICU) to the surgical ICU during the study period revealed a lower incidence ratio for CRBSI in the MICU (0.16, 95% CI, 0.05 – 0.44, p = 0.001).
Barsuk et al. (2009)73 | Observational cohort study | Minimum proficiency/mastery model on standardized checklist of CVC insertion with expert panel review of performance using a high-fidelity partial task trainer with computer interface, simulation exercises performed with deliberate practice and individualized feedback components | PGY-2 and PGY-3 internal medicine residents (n = 41) performed 46 internal jugular and subclavian CVCs | In the medical ICU of a single academic institution, although the groups did not differ significantly regarding complications (pneumothorax, arterial puncture or CVC adjustment), the simulator-trained group required fewer needle passes (M = 1.79, SD = 1.0) than the traditionally trained group (M = 2.78, SD = 1.77, p = 0.04).
Britt et al. (2009)89 | Randomized controlled trial | Minimum proficiency model with deliberate practice and individualized feedback from attending surgeon on a partial-task high-fidelity trainer, added to standard lecture on CVC technique | Junior surgical residents (n = 34, PGY-NR) that had not completed a trauma ICU rotation performed 73 ultrasound-guided and subclavian CVCs | At a single Level I trauma teaching hospital ICU, a higher level of comfort and ability was found in the simulator-trained group (p = 0.03). The simulator-trained group outperformed the traditionally-trained group in 7 of 10 performance variables measured, although none of these were statistically significant. More complications (pneumothorax, arterial puncture, inability to complete the procedure) were found in the traditional group than in the simulator-trained group (p = 0.07).
Evans (2010)85 | Randomized controlled, blinded, trial | Minimum proficiency model with deliberate practice and individualized feedback from attending surgeon on a partial-task high fidelity trainer, added to standard lecture on CVC technique | PGY-1 and PGY-2 residents from emergency medicine, internal medicine, general surgery, anesthesia, and obstetrics-gynecology (n = 115) performed a total 495 internal jugular, subclavian, and femoral vein CVCs | In the emergency department, medical ICU, and surgical ICU at a single teaching hospital, simulation-trained residents succeeded in cannulation with first attempt more often (51% vs. 37%, p = 0.03) and successfully inserted the catheter on their first attempt more often (78% vs. 67%, p = 0.02). No differences seen between groups on measures of technical errors such as standard precautions, insertion steps, and use of sterile technique, or on measures of mechanical complications (e.g., pneumothorax, transient arrhythmia, catheter tip malposition, or arterial puncture).
Khouli, et al. (2011)90 | Randomized controlled, blinded, trial | Full-immersion operation room simulation, including partial task trainer, in addition to video training and structured assessment training on sterile techniques. | PGY-2 and PGY-3 internal medicine (n = 47), and subsequently emergency residents (n = 58 total) with prior certification in CVC placement, number of CVCs performed NR | At a single academic hospital, the simulator plus video-trained group had higher median scores than the video-only group on a survey of preparedness and confidence (p < 0 .001). After additional simulator training with both emergency and internal medicine residents (n = 58), the rate of CRBSI among patients in the MICU decreased from 3.5 per 1,000 catheter days prior to the intervention to 1.0 per 1,000 catheter-days after the intervention. The rate of CRBSI remained steady in the surgical ICU over that same time period - 3.4 per 1,000, where surgical residents had received traditional training during the study period.
Martin et al. (2003) | Pre-post observational cohort design, compared with historical cohort | Didactic training on anatomy and CVC techniques coupled with supervised practice on fresh human cadavers, whereby supervisors provided immediate individualized feedback on performance as well as video tape review with debriefing | Medical students trained in their 4^th^ year, performing CVC during PGY-1, number of total CVCs performed by health system ranged from 1,682 – 1,884 annually | In a two-hospital academic health system, across the emergency, surgery, and critical care, the incidence of pneumothorax decreased significantly (p = 0.004) after implementing the simulation-based training program. When limiting analyses to the initial 3-month period that residents would begin the rotation, the incidence of pneumothorax dropped from 34.0% to 3.8% after implementing simulation.
Miranda et al. (2007)94 | Prospective controlled cohort design | Follow didactic training, practice in placing CVC and sterile technique was overseen by experienced residents and attending internists | Internal medicine residents (n = 150, PGY-NR) performed 54 internal jugular and subclavian CVCs | In the general medical service at a single academic teaching hospital, femoral vein catheterizations decreased non-significantly in the simulation-trained group. The simulation group was more likely to use masks during the procedure (risk ratio 2.2, 95% CI, 1.3-2.7, p = 0.008), but there was no difference between groups in the proper use of other sterile techniques. There was no difference between groups in the rate of CRBSI per 1,000 catheter-days. The simulation group demonstrated significantly increased knowledge of complications of femoral vein catheterizations.
Sherertz et al. (2000) 91 | Pre-post, non-randomized observational design | One hour course on basic infection control, followed by 1 hour of simulation with mannequins for practicing blood stream access techniques (including CVC) in the presence of senior clinical staff | 3^rd^ year medical students and PGY-1 physicians (n > 100, actual number NR), total CVCs performed at system during study period 5,099 | Medical students' and physicians' perceived need for full-sized sterile drapes increased from 22% prior to the course to 73% 6 months after the course (p < 0.001). Across six ICUs and one step-down unit at a single academic institution, the documented use of full-size sterile drapes increased from 44% to 65% (p < 0.001), and the CRBSI rate decreased from 4.51 per 1,000 patient days prior to the course to 2.92 per 1,000 patient days 18 months after the course. The estimated cost savings of decreases in CRBSI is between $63,000 and $800,000.
Smith et al. (2010)87 | Randomized controlled trial | Didactic training followed by partial task trainer practice of entire CVC placement under supervision with immediate feedback, simulation group was then allowed to continue simulated practice unsupervised | Internal medicine residents PGY-1 and PGY-2 (n = 52), number of CVCs performed NR | At medical ICU of a single teaching hospital, the simulation group demonstrated a non-significantly improved performance on a number of structured checklist items in initial simulation tasks (13.2, SD = 4.9 vs. 9.7, SD = 5.0, p = 0.07). No differences observed between groups in adverse outcomes or complications of CVC placement.
Velmahos et al. (2004)92 | Randomized controlled trial | Three hour CVC surgical skills course consisting of didactic training, and small group practice with high-fidelity mannequin and supervising instructor; each intern practiced CVC insertion a minimum of 4 times in the exercise | Surgical interns (n = 28), number of CVCs performed NR | In a single academic surgery department, scores on a CVC technical competency exam were similar between groups on the pretest; however, the simulation-trained group scored significantly higher on the posttest (p = 0.03). The simulation group also achieved a significantly higher score (p < 0.001) on structured checklist evaluation of performance during CVC placement and required fewer attempts to find the vein (p = 0.046).

Catheter-related blood stream infection (CRBSI), Intensive care unit (ICU), Not reported (NR), Post-graduate year (PGY).

### Harms

Studies included in this review generally provided additive or supplemental interventions to training as usual, and no study reported data indicating increased potential for or actual harm to patients that resulted from implementing simulation techniques. However, it is conceivable that simulation exercises would place demand on valuable resources that could be applied elsewhere in patient safety efforts. Such considerations were not evaluated in literature captured for this review.

## How Has the Patient Safety Practice Been Implemented and in What Context?

### Context for Simulation

A meta-analysis of computer-aided simulation in education programs for health professionals determined that 564 of the 609 studies included in the review (92.6%) examined effects of simulation provided through dedicated simulation centers. Thirty-four additional studies (5.6%) examined simulation provided in the clinical environment, and 11 studies (1.8%) reported from both contexts.31 Across studies cited in this review that reported the context in which simulation was implemented, academic medical systems and academically-affiliated hospitals predominate.48,51,53-56,59-64,68,73,76,83,85-92 However, studies also reported outcomes specific to implementing simulation in tertiary care facilities,52,68,85,87 in trauma centers,69,89 and in multispecialty medical groups.65,66 Only one study in our review reported patient outcomes by care setting63; however, these outcomes are not specific to the simulation training site but to a subsequent external training placement.

### Implementing Simulation

Gaba conceptualized a framework that captures the versatility of simulation.24 In this framework, each of 11 dimensions assist those looking to implement simulation to define their needs and goals: (1) the purpose and aims of simulation activity; (2) the unit of participation in the simulation—individuals or teams; (3) the experience level of simulation participants; (4) the health care domain in which the simulation is applied; (5) the health care disciplines of personnel participating in the simulation; (6) the type of knowledge, skill, attitudes, or behavior addressed in simulation; (7) the age of the patient being simulated; (8) the technology applicable or required for simulations; (9) the site of simulation—in situ clinical setting versus dedicated simulation center; (10) the extent of direct participation; and (11) the feedback method accompanying simulation. Gaba further delineates implementation mechanisms for health care settings as well as a variety of professional and governmental organizations.

In addition to the 11-dimensional framework by Gaba,24 which lays out implementable aspects of types of simulation, a number of other factors must be considered before using simulation:95

1. People: are both trainee and training participants available and appropriately trained in simulation techniques?
2. Time: is sufficient time dedicated to meaningful simulations not only as adjunctive training experiences provided in the flow of regular care activities?
3. Equipment: are simulation-specific materials (e.g., mannequin) and actual medical equipment or devices available to recreate a desirable realism in simulated environments?
4. Space: is adequate space available for dedicating to simulated environments? Even in-situ simulations will require storage and preparation of materials.
5. Supplies: if the simulation requires the use of real medical supplies, are these available?
6. Technical Support: implementation phases, especially of high-tech or complex simulators, may require support, and there may be upkeep and maintenance to simulation equipment.

People and time are likely to be the most expensive aspects of simulation in the long run. However, startup costs vary substantially with the complexity of the simulation, which also depends on the purpose. Large simulation centers may find financial support in philanthropic sources or may be subsidized by participants and other organizational entities. Other expenses will include the upkeep of simulation equipment and space dedicated to simulation.

Rosen and colleagues discussed the importance of considering components most likely to enhance success in simulation techniques. For example, these authors differentiate the importance of cognitive fidelity in a simulated exercise from physical fidelity. That is, simulations that engage the participant in ways that, cognitively, most reflect the actual task are likely to be more effective.25 Debriefing is considered crucial when implementing simulation,25,26 a recommended best practice according to one review of simulation-based medical education.96 Other national efforts have delineated future directions for simulation research.97 At an international level, researchers have identified three primary foci to further understanding of best practices in simulation: instructional design, outcomes measurement, and translational activities.98

## Are There Any Data About Costs?

The cost of implementing simulation exercises varies from low to high depending on type of exercise and the personnel and equipment resources involved. In addition, start-up costs for a comprehensive simulation center may be accounted for differently than ongoing costs for exercises, which complicates the ability to categorize the expected cost for simulation as a patient safety practice. Future and ongoing investigations will give us further insight into the cost-effectiveness of simulation exercises in general, and simulation that targets improvement in patient safety. Unfortunately, research addressing cost savings attributable directly to simulation remains sparse, but research has reported up to a 7-to-1 return on simulation costs through the reduction in hospital days for blood stream infection.91,99

## Are There Any Data About the Effect of Context on Effectiveness?

This review did not find published data about the effect of context on the effectiveness of simulation exercises to improve patient safety. Therefore, this is an area for future research.

## Conclusions and Comment

Simulation has continued to garner momentum in patient safety efforts in the past decade. Various professional organizations have endorsed the use of simulation through accreditation standards, and government agencies have continued to fund investigations into the use of simulation for enhancing care. On a basic level, simulation allows for exercising and improving aspects of health care without risk to patients. Simulation has been utilized in patient safety for the purposes of education, assessment, research, and integrating system-level practices. These efforts have been reported in the literature as research about simulation, that is, research that can help elucidate and understand leverage points in enhancing patient safety. In the past decade, researchers have also begun focusing on using simulation, which has increased our understanding of benefits (especially with respect to patient outcomes) likely to be realized in the translation of simulation techniques into practice.

The review found that studies reporting outcomes with actual patients, or systems of care, have occurred primarily in academic settings, although researchers have reported on the use of simulation for a variety of clinical specialties, experience levels, and care settings. These studies varied in terms of individual quality, but the bulk of studies were randomized or methodologically controlled designs. Researchers have replicated standardized simulation training for CVC placement, and although promising for patient safety in CVC, we did not find other examples of replication studies in our review. We did not find analysis of contextual effects (e.g., MICU analyzed against SICU) on the validity of simulation to improve patient safety. Thus the transferability of simulation techniques to increase patient safety similarly to that reported in this review remains unknown. It is likely that these results will generalize to other settings, but generalizability of any one technique is likely to vary depending on a number of factors such as those in Gaba's 11-dimensional framework24 and adequacy of resources dedicated to simulation (e.g., debriefing).

At this juncture, simulation appears to have a favorable impact on quicker acquisition and improved performance of technical skills. Although not yet thoroughly studied, simulating complex or high-stakes procedures appears to be a promising technique to increase patient-safe behavior at the clinician- and team-levels. Simulation has the potential to enhance patient safety through structured assessment and debriefing in quality improvement initiatives. It has been used to assess practices that would be difficult or unsafe to study empirically in real-time with actual patients. Likewise, simulation has been endorsed for ongoing competency and continuing education, as well as advancing to mastery-level practices.

Previous systematic reviews have reported that simulation contributes to enhanced knowledge acquisition and improved clinical performance.29 Simulation techniques have been utilized in translating results from within simulation lab to patient and health care system-level outcomes.100 Protecting time for debriefing in a learning experience has been suggested as a crucial component to simulation techniques in a systematic review.101 This review is the first to examine effects that simulation exercises exert on patient safety outcomes, and in particular, outcomes with patients outside of simulation laboratory settings (i.e., during clinical care).

Reviewing the literature on simulation approaches broadly resulted in several limitations. First, it is possible broad search strategies missed studies that may otherwise be captured with targeted and comprehensive strategies dedicated to each simulation technique, clinical specialty, or application. Second, given relative infancy of the research into simulation exercises, the field may be prone to selective reporting of studies with positive findings, leading to potential publication bias in our review. Third, we limited our assessment of quality of evidence to study design and did not perform structured assessment of the strength of evidence. Therefore, overall strength of the evidence for simulation exercises to improve patient safety should be interpreted with caution based on the current review.

Simulation is a versatile technique that continues to garner momentum in a variety of clinical settings and applications, including patient safety strategies. Although evidence is largely heterogeneous at this time, our review suggests potential for simulation exercises to contribute to patient safety through increased technical and procedural performance, and through improved team performance. Limited research using health system-level observations suggests that simulation may enhance patient safety, although more research is needed on the potential for simulation to contribute to system-level differences in patient safety outcomes. Systematic reviews of simulation for specific procedures have begun reporting patient safety outcomes,57,102 and more reviews of this nature would enhance our understanding of the overall contribution of simulation techniques to patient safety. Future systematic reviews would benefit from investigators using a consistent framework to describe the intervention, its context and its implementation, such as Gaba's framework.

Simulation implies a spirit of innovation in a world with quickly evolving technologies. As a specialty field, it may be in an “end of the beginning” phase, and some of the benefits of simulation may not be realized from a short-term perspective.24 As a developing field, certain aspects may remain under discussion, such as standardized definitions of “validity” in simulated environments.103 However, the breadth of applications and even purposes has not yet been fully realized.24 As only one further example of simulation's potential role in making care better and safer, a recent systematic review of simulation and video games for patients post-stroke reported increased upper extremity functionality.104 A summary table is located in Table 2.

Table 2, Chapter 38 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate-to-high | Moderate to high for specific topics | Uncertain | Moderate^*^ | Moderate

* Cost varies based on the simulation technique and resources involved. For example, exercises involving fully simulated operating room environments may have higher costs to implement relative to those that require a simple mannequin or patient actors.

## References

1 Chang Y, Mark B. Effects of learning climate and registered nurse staffing on medication errors. Nurs Res. 2011;60(1):32-9. [pmid: 21127452].
2 Rogers SO Jr., Gawande AA, Kwaan M, et al. Analysis of surgical errors in closed malpractice claims at 4 liability insurers. Surgery. 2006;140(1):25-33. [pmid: 16857439].
3 Meltzer D, Manning WG, Morrison J, et al. Effects of physician experience on costs and outcomes on an academic general medicine service: results of a trial of hospitalists. Ann Intern Med. 2002;137(11):866-74. [pmid: 12458986].
4 Singh H, Thomas EJ, Petersen LA, et al. Medical errors involving trainees: a study of closed malpractice claims from 5 insurers. Arch Intern Med. 2007;167(19):2030-6. [pmid: 17954795].
5 Cooke M, Irby DM, Sullivan W, et al. American medical education 100 years after the Flexner report. N Engl J Med. 2006;355(13):1339-44. [pmid: 17005951].
6 Ziv A, Wolpe PR, Small SD, et al. Simulation-based medical education: an ethical imperative. Acad Med. 2003;78(8):783-8. [pmid: 12915366].
7 Ericsson KA. Deliberate practice and acquisition of expert performance: a general overview. Acad Emerg Med. 2008;15(11):988-94. [pmid: 18778378].
8 Ericsson KA. Deliberate practice and the acquisition and maintenance of expert performance in medicine and related domains. Acad Med. 2004;79(10 Suppl):S70-81. [pmid: 15383395].
9 Regenbogen SE, Greenberg CC, Studdert DM, et al. Patterns of technical error among surgical malpractice claims: an analysis of strategies to prevent injury to surgical patients. Ann Surg. 2007;246(5):705-11. [pmid: 17968158].
10 Semeraro F, Signore L, Cerchiari EL. Retention of CPR performance in anaesthetists. Resuscitation. 2006;68(1):101-8. [pmid: 16325986].
11 O'Steen DS, Kee CC, Minick MP. The retention of advanced cardiac life support knowledge among registered nurses. J Nurs Staff Dev. 1996;12(2):66-72. [pmid: 8715621].
12 Park CS. Simulation and quality improvement in anesthesiology. Anesthesiol Clin. 2011;29(1):13-28. [pmid: 21295750].
13 Gaba DM, Fish KJ, Howard SK. Crisis management in anesthesiology. New York. Churchill Livingstone. 1994.
14 Kohn LT, Corrigan J, Donaldson MS. To err is human : building a safer health system. Washington, D.C. National Academy Press. 2000.
15 Institute of Medicine (U.S.). Committee on Quality of Health Care in America. Crossing the quality chasm : a new health system for the 21st century. Washington, D.C. National Academy Press. 2001.
16 Improving Patient Safety Through Simulation Research. June. 2008. Agency for Healthcare Research and Quality. Rockville, MD. www.ahrq.gov/qual/simulproj.htm.
17 Improving Patient Safety Through Simulation Research: Funded Projects. AHRQ Publication No. 11-P012-EF. September. 2011. Agency for Healthcare Research and Quality. Rockville, MD. www.ahrq.gov/qual/simulproj11.htm.
18 Johnson KA, Sachdeva AK, Pellegrini CA. The critical role of accreditation in establishing the ACS Education Institutes to advance patient safety through simulation. J Gastrointest Surg. 2008;12(2):207-9. [pmid: 17972142].
19 Nehring WM. U.S. boards of nursing and the use of high-fidelity patient simulators in nursing education. J Prof Nurs. 2008;24(2):109-17. [pmid: 18358446].
20 Steadman RH. The American Society of Anesthesiologists' national endorsement program for simulation centers. J Crit Care. 2008;23(2):203-6. [pmid: 18538213].
21 Buck GH. Development of simulators in medical education. Gesnerus. 1991;48 Pt 1:7-28. [pmid: 1855669].
22 Nehring WM, Lashley FR. Nursing simulation: A review of the past 40 years. Simul Gaming. 2009;40:528-52.
23 Abrahamson S, Denson JS, Wolf RM. Effectiveness of a simulator in training anesthesiology residents. J Med Educ. 1969;44(6):515-9. [pmid: 5789592].
24 Gaba DM. The future vision of simulation in healthcare. Simul Healthc. 2007;2(2):126-35. [pmid: 19088617].
25 Rosen MA, Salas E, Tannenbaum SI, et al. Simulation-based training for teams in health care: Designing scenarios, measuring performance, and providing feedback. Carayon P, editor. Handbook of HFE in health care and patient safety. 2nd Ed. Boca Raton, FL. CRC Press. 2011:571-92.
26 Fanning RM, Gaba DM. The role of debriefing in simulation-based learning. Simul Healthc. 2007;2(2):115-25. [pmid: 19088616].
27 Rudolph JW, Simon R, Rivard P, et al. Debriefing with good judgment: combining rigorous feedback with genuine inquiry. Anesthesiol Clin. 2007;25(2):361-76. [pmid: 17574196].
28 Gaba DM. The future's here. We are it. Simul Healthc. 2006;1:1-2. [pmid: 19088564].
29 McGaghie WC, Issenberg SB, Cohen ER, et al. Does simulation-based medical education with deliberate practice yield better results than traditional clinical education? A meta-analytic comparative review of the evidence. Acad Med. 2011;86(6):706-11. [pmid: 21512370].
30 Cook DA, Erwin PJ, Triola MM. Computerized virtual patients in health professions education: a systematic review and meta-analysis. Acad Med. 2010;85(10):1589-602. [pmid: 20703150].
31 Cook DA, Hatala R, Brydges R, et al. Technology-enhanced simulation for health professions education: a systematic review and meta-analysis. JAMA. 2011;306(9):978-88. [pmid: 21900138].
32 Kobayashi L, Shapiro MJ, Suner S, et al. Disaster medicine: the potential role of high fidelity medical simulation for mass casualty incident training. Med Health R I. 2003;86(7):196-200. [pmid: 12973894].
33 Mishra A, Catchpole K, Dale T, et al. The influence of non-technical performance on technical outcome in laparoscopic cholecystectomy. Surg Endosc. 2008;22(1):68-73. [pmid: 17479324].
34 Gaba DM, Howard SK, Fish KJ, et al. Simulation-based training in Anesthesia Crisis Resource Management (ACRM): A decade of experience. Simul Gaming. 2001;32:175-93.
35 Blum RH, Raemer DB, Carroll JS, et al. A method for measuring the effectiveness of simulation-based team training for improving communication skills. Anesth Analg. 2005;100(5):1375-80. table of contents. [pmid: 15845689].
36 Pian-Smith MC, Simon R, Minehart RD, et al. Teaching residents the two-challenge rule: a simulation-based approach to improve education and patient safety. Simul Healthc. 2009;4(2):84-91. [pmid: 19444045].
37 Morgan PJ, Tarshis J, LeBlanc V, et al. Efficacy of high-fidelity simulation debriefing on the performance of practicing anaesthetists in simulated scenarios. Br J Anaesth. 2009;103(4):531-7. [pmid: 19703938].
38 Dalley P, Robinson B, Weller J, et al. The use of high-fidelity human patient simulation and the introduction of new anesthesia delivery systems. Anesth Analg. 2004;99(6):1737-41. table of contents. [pmid: 15562063].
39 Coopmans VC, Biddle C. CRNA performance using a handheld, computerized, decision-making aid during critical events in a simulated environment: a methodologic inquiry. AANA J. 2008;76(1):29-35. [pmid: 18323317].
40 Lipman S, Daniels K, Cohen SE, et al. Labor room setting compared with the operating room for simulated perimortem cesarean delivery: a randomized controlled trial. Obstet Gynecol. 2011;118(5):1090-4. [pmid: 22015877].
41 Wayne DB, Didwania A, Feinglass J, et al. Simulation-based education improves quality of care during cardiac arrest team responses at an academic teaching hospital: a case-control study. Chest. 2008;133(1):56-61. [pmid: 17573509].
42 Wayne DB, Butter J, Siddall VJ, et al. Mastery learning of advanced cardiac life support skills by internal medicine residents using simulation technology and deliberate practice. J Gen Intern Med. 2006;21(3):251-6. [pmid: 16637824].
43 Wayne DB, Siddall VJ, Butter J, et al. A longitudinal study of internal medicine residents' retention of advanced cardiac life support skills. Acad Med. 2006;81(10 Suppl):S9-S12. [pmid: 17001145].
44 Daniels K, Lipman S, Harney K, et al. Use of simulation based team training for obstetric crises in resident education. Simul Healthc. 2008;3(3):154-60. [pmid: 19088659].
45 Lighthall GK, Poon T, Harrison TK. Using in situ simulation to improve in-hospital cardiopulmonary resuscitation. Jt Comm J Qual Patient Saf. 2010;36(5):209-16. [pmid: 20480753].
46 Marshall S, Harrison J, Flanagan B. The teaching of a structured tool improves the clarity and content of interprofessional clinical communication. Qual Saf Health Care. 2009;18(2):137-40. [pmid: 19342529].
47 McGaghie WC. Medical education research as translational science. Sci Transl Med. 2010;2(19):19cm8. [pmid: 20371485].
48 Cohen J, Cohen SA, Vora KC, et al. Multicenter, randomized, controlled trial of virtual-reality simulator training in acquisition of competency in colonoscopy. Gastrointest Endosc. 2006;64(3):361-8. [pmid: 16923483].
49 Sedlack RE, Kolars JC. Computer simulator training enhances the competency of gastroenterology fellows at colonoscopy: results of a pilot study. Am J Gastroenterol. 2004;99(1):33-7. [pmid: 14687137].
50 Ahlberg G, Hultcrantz R, Jaramillo E, et al. Virtual reality colonoscopy simulation: a compulsory practice for the future colonoscopist?. Endoscopy. 2005;37(12):1198-204. [pmid: 16329017].
51 Park J, MacRae H, Musselman LJ, et al. Randomized controlled trial of virtual reality simulator training: transfer to live patients. Am J Surg. 2007;194(2):205-11. [pmid: 17618805].
52 Thomson M, Heuschkel R, Donaldson N, et al. Acquisition of competence in paediatric ileocolonoscopy with virtual endoscopy training. J Pediatr Gastroenterol Nutr. 2006;43(5):699-701. [pmid: 17130753].
53 Ferlitsch A, Schoefl R, Puespoek A, et al. Effect of virtual endoscopy simulator training on performance of upper gastrointestinal endoscopy in patients: a randomized controlled trial. Endoscopy. 2010;42(12):1049-56. [pmid: 20972956].
54 Blum MG, Powers TW, Sundaresan S. Bronchoscopy simulator effectively prepares junior residents to competently perform basic clinical bronchoscopy. Ann Thorac Surg. 2004;78(1):287-91. discussion - 91. [pmid: 15223446].
55 Duncan DR, Morgenthaler TI, Ryu JH, et al. Reducing iatrogenic risk in thoracentesis: establishing best practice via experiential training in a zero-risk environment. Chest. 2009;135(5):1315-20. [pmid: 19017865].
56 Tongprasert F, Wanapirak C, Sirichotiyakul S, et al. Training in cordocentesis: the first 50 case experience with and without a cordocentesis training model. Prenat Diagn. 2010;30(5):467-70. [pmid: 20440735].
57 Gurusamy KS, Aggarwal R, Palanivelu L, et al. Virtual reality training for surgical trainees in laparoscopic surgery. Cochrane Database Syst Rev. 2009;(1):CD006575. [pmid: 19160288].
58 Ahlberg G, Enochsson L, Gallagher AG, et al. Proficiency-based virtual reality training significantly reduces the error rate for residents during their first 10 laparoscopic cholecystectomies. Am J Surg. 2007;193(6):797-804. [pmid: 17512301].
59 Calatayud D, Arora S, Aggarwal R, et al. Warm-up in a virtual reality environment improves performance in the operating room. Ann Surg. 2010;251(6):1181-5. [pmid: 20485133].
60 Hamilton EC, Scott DJ, Kapoor A, et al. Improving operative performance using a laparoscopic hernia simulator. Am J Surg. 2001;182(6):725-8. [pmid: 11839347].
61 Kallstrom R, Hjertberg H, Svanvik J. Impact of virtual reality-simulated training on urology residents' performance of transurethral resection of the prostate. J Endourol. 2010;24(9):1521-8. [pmid: 20677993].
62 Gaies MG, Morris SA, Hafler JP, et al. Reforming procedural skills training for pediatric residents: a randomized, interventional trial. Pediatrics. 2009;124(2):610-9. [pmid: 19651582].
63 Sears K, Goldsworthy S, Goodman WM. The relationship between simulation in nursing education and medication safety. J Nurs Educ. 2010;49(1):52-5. [pmid: 19810664].
64 Hall RE, Plant JR, Bands CJ, et al. Human patient simulation is effective for teaching paramedic students endotracheal intubation. Acad Emerg Med. 2005;12(9):850-5. [pmid: 16141019].
65 Draycott T, Sibanda T, Owen L, et al. Does training in obstetric emergencies improve neonatal outcome?. BJOG. 2006;113(2):177-82. [pmid: 16411995].
66 O'Connor PJ, Sperl-Hillen JM, Johnson PE, et al. Simulated physician learning intervention to improve safety and quality of diabetes care: a randomized trial. Diabetes Care. 2009;32(4):585-90. [pmid: 19171723].
67 Bruppacher HR, Alam SK, LeBlanc VR, et al. Simulation-based training improves physicians' performance in patient care in high-stakes clinical setting of cardiac surgery. Anesthesiology. 2010;112(4):985-92. [pmid: 20234305].
68 Weidman EK, Bell G, Walsh D, et al. Assessing the impact of immersive simulation on clinical performance during actual in-hospital cardiac arrest with CPR-sensing technology: A randomized feasibility study. Resuscitation. 2010;81(11):1556-61. [pmid: 20724057].
69 Capella J, Smith S, Philp A, et al. Teamwork training improves the clinical care of trauma patients. J Surg Educ. 2010;67(6):439-43. [pmid: 21156305].
70 Berenholtz SM, Pronovost PJ, Lipsett PA, et al. Eliminating catheter-related bloodstream infections in the intensive care unit. Crit Care Med. 2004;32(10):2014-20. [pmid: 15483409].
71 Mermel LA. Prevention of intravascular catheter-related infections. Ann Intern Med. 2000;132(5):391-402. [pmid: 10691590].
72 Pittet D, Tarara D, Wenzel RP. Nosocomial bloodstream infection in critically ill patients. Excess length of stay, extra costs, and attributable mortality. JAMA. 1994;271(20):1598-601. [pmid: 8182812].
73 Barsuk JH, McGaghie WC, Cohen ER, et al. Use of simulation-based mastery learning to improve the quality of central venous catheter placement in a medical intensive care unit. J Hosp Med. 2009;4(7):397-403. [pmid: 19753568].
74 National Quality Forum (NQF). Safe practices for better healthcare - 2010 update: A consensus report. Washington D.C. NQF. 2010.
75 Agency for Healthcare Research and Quality. Guide to the Patient Safety Indicators v4.3. Rockville, MD. 2011.
76 Barsuk JH, Cohen ER, Feinglass J, et al. Use of simulation-based education to reduce catheter-related bloodstream infections. Arch Intern Med. 2009;169(15):1420-3. [pmid: 19667306].
77 American Board of Internal Medicine. Policies and procedures required for internal medicine. www.abim.org/certification/policies/imss/im.aspx. December 15, 2011.
78 American Board of Emergency Medicine. Model of the clinical practice of emergency medicine. www.abem.org/PUBLIC/portal/alias__Rainbow/lang__en-US/tabID__4223/DesktopDefault.aspx. December 15, 2011. 2009.
79 Huang GC, Smith CC, Gordon CE, et al. Beyond the comfort zone: residents assess their comfort performing inpatient medical procedures. Am J Med. 2006;119(1):71 e17-24. [pmid: 16431194].
80 Seymour NE, Gallagher AG, Roman SA, et al. Virtual reality training improves operating room performance: results of a randomized, double-blinded study. Ann Surg. 2002;236(4):458-63. discussion 63-4. [pmid: 12368674].
81 Ma IW, Brindle ME, Ronksley PE, et al. Use of simulation-based education to improve outcomes of central venous catheterization: a systematic review and meta-analysis. Acad Med. 2011;86(9):1137-47. [pmid: 21785310].
82 Macnab AJ, Macnab M. Teaching pediatric procedures: the Vancouver model for instructing Seldinger's technique of central venous access via the femoral vein. Pediatrics. 1999;103(1):E8. [pmid: 9917488].
83 Barsuk JH, Ahya SN, Cohen ER, et al. Mastery learning of temporary hemodialysis catheter insertion by nephrology fellows using simulation technology and deliberate practice. Am J Kidney Dis. 2009;54(1):70-6. [pmid: 19376620].
84 Barsuk JH, Cohen ER, Feinglass J, et al. Unexpected Collateral Effects of Simulation-Based Medical Education. Acad Med. 2011. [pmid: 22030762].
85 Evans LV, Dodge KL, Shah TD, et al. Simulation training in central venous catheter insertion: improved performance in clinical practice. Acad Med. 2010;85(9):1462-9. [pmid: 20736674].
86 Griswold-Theodorson S, Hannan H, Handly N, et al. Improving patient safety with ultrasonography guidance during internal jugular central venous catheter placement by novice practitioners. Simul Healthc. 2009;4(4):212-6. [pmid: 21330794].
87 Smith CC, Huang GC, Newman LR, et al. Simulation training and its effect on long-term resident performance in central venous catheterization. Simul Healthc. 2010;5(3):146-51. [pmid: 20651476].
88 Barsuk JH, McGaghie WC, Cohen ER, et al. Simulation-based mastery learning reduces complications during central venous catheter insertion in a medical intensive care unit. Crit Care Med. 2009;37(10):2697-701. [pmid: 19885989].
89 Britt RC, Novosel TJ, Britt LD, et al. The impact of central line simulation before the ICU experience. Am J Surg. 2009;197(4):533-6. [pmid: 19249739].
90 Khouli H, Jahnes K, Shapiro J, et al. Performance of medical residents in sterile techniques during central vein catheterization: randomized trial of efficacy of simulation-based training. Chest. 2011;139(1):80-7. [pmid: 20705795].
91 Sherertz RJ, Ely EW, Westbrook DM, et al. Education of physicians-in-training can decrease the risk for vascular catheter infection. Ann Intern Med. 2000;132(8):641-8. [pmid: 10766683].
92 Velmahos GC, Toutouzas KG, Sillin LF, et al. Cognitive task analysis for teaching technical skills in an inanimate surgical skills laboratory. Am J Surg. 2004;187(1):114-9. [pmid: 14706600].
93 Andreatta P, Chen Y, Marsh M, et al. Simulation-based training improves applied clinical placement of ultrasound-guided PICCs. Support Care Cancer. 2011;19(4):539-43. [pmid: 20306091].
94 Miranda JA, Trick WE, Evans AT, et al. Firm-based trial to improve central venous catheter insertion practices. J Hosp Med. 2007;2(3):135-42. [pmid: 17549773].
95 David M. Gaba Personal communication. December. 15. 2011.
96 McGaghie WC, Issenberg SB, Petrusa ER, et al. A critical review of simulation-based medical education research: 2003-2009. Med Educ. 2010;44(1):50-63. [pmid: 20078756].
97 Van Hook JE. Building a national agenda for simulation-based medical education. U.S. Army Medical Research and Materiel Command. (Contract No. W81XWH-04-1-0583). Washington D.C. 2004.
98 Issenberg SB, Ringsted C, Ostergaard D, et al. Setting a research agenda for simulation-based healthcare education: a synthesis of the outcome from an Utstein style meeting. Simul Healthc. 2011;6(3):155-67. [pmid: 21642804].
99 Cohen ER, Feinglass J, Barsuk JH, et al. Cost savings from reduced catheter-related bloodstream infection after simulation-based education for residents in a medical intensive care unit. Simul Healthc. 2010;5(2):98-102. [pmid: 20389233].
100 McGaghie WC, Draycott TJ, Dunn WF, et al. Evaluating the impact of simulation on translational patient outcomes. Simul Healthc. 2011;6(Suppl):S42-7. [pmid: 21705966].
101 McGaghie WC, Issenberg SB, Petrusa ER, et al. Effect of practice on standardised learning outcomes in simulation-based medical education. Med Educ. 2006;40(8):792-7. [pmid: 16869926].
102 Walsh CM, Sherlock ME, Ling SC, et al. Virtual reality simulation training for health professions trainees in gastrointestinal endoscopy. Cochrane Database Syst Rev. 2012;6:CD008237. [pmid: 22696375].
103 Schout BM, Hendrikx AJ, Scheele F, et al. Validation and implementation of surgical simulators: a critical review of present, past, and future. Surg Endosc. 2010;24(3):536-46. [pmid: 19633886].
104 Laver KE, George S, Thomas S, et al. Virtual reality for stroke rehabilitation. Cochrane Database Syst Rev. 2011;9:CD008349. [pmid: 21901720].