# Monitoring Patient Safety Problems (NEW)

## How Important Is the Problem?

Adverse events (AEs) associated with medical treatments are a major source of morbidity and mortality.1-4 Studies showed that the incidence of AEs varied from 3 percent to 17 percent of hospitalized patients,5 and about 50 percent of the AEs were judged to be preventable. Most AEs resulted in minor or temporary disability, but a proportion of the AEs, 4 percent to 21 percent, contributed to death.5

In 1999, the Institute of Medicine (IOM) published a landmark report on medical errors titled “To Err Is Human: Building a Safer Health Care System.”6 Since IOM released the report, several studies have examined progress in patient safety and have found little evidence of systematic improvements in the health care system.1,7-10 According to a 2008 Healthcare Cost and Utilization Project statistical brief, drug-related adverse outcomes were noted in nearly 1.9 million inpatient hospital stays (4.7% of all stays) and 838,000 treat-and-release emergency department visits (0.8% of all visits).10 The Institute for Healthcare Improvement estimated that nearly 15 million instances of medical harm occur in the United States (U.S.) each year.11 Over the five years from 2004 to 2008, drug-related adverse outcomes in the inpatient setting increased by 52 percent.10 This increase in AEs could be the result of the intensified effort in incident reporting; still, keeping patients from being harmed by preventable medical errors will continue to be a challenging goal for the medical community.

As used in this review, an AE is defined as an event that results in unintended harm to the patient by an act of commission or omission rather than by the underlying disease or condition of the patient.12 A medical error is the failure of a planned action to be completed as intended or the use of a wrong plan to achieve an aim.12 AEs include medical errors as well as more general substandard care that can result in harm, such as harm caused by incorrect diagnoses or lack of patient monitoring during treatment.13 Therefore, AEs do not always involve errors, negligence, or poor quality of care and may not always be preventable.

“Near miss” is another term often used in patient safety monitoring. It is defined as an event or a situation that did not produce patient harm, but only because of intervening factors, such as patient health or timely intervention.12

## What Is the Patient Safety Practice?

Health care organizations use a wide array of methods to uncover and monitor AEs and errors in medical care. These methods include incident reporting, direct observation of patient care, chart review, analysis of malpractice claims, patient complaints and reports to risk management, executive walk rounds, trigger-tool use, patient interviews, morbidity and mortality conferences, autopsy, and clinical surveillance.14-19 These methods vary in the timing of finding AEs (retrospective or “real-time”), and each has advantages and limitations.14-18

Historically, medical errors were revealed retrospectively through morbidity and mortality committees, autopsy, and malpractice claims data.6,14-16,18 While these methods provide valuable information on medical errors, they are not appropriate for measuring the incidence or prevalence of the errors or events. They might also be limited by hindsight bias (e.g., a tendency to rate care in the context of a bad outcome as substandard), if the evaluators are not blinded to outcome.15

Chart review was often used as the benchmark for estimating the extent of medical harms in hospitals or as the gold standard in patient safety studies to quantify AE rates.15,16 However, chart review is generally resource-intensive.15 Incomplete documentation in the medical record can affect the ability to detect the potential causes of AEs.15 Near misses that produce no injury are rarely detected by this method.15,16 The reliability (precision) of the judgments about the presence of AEs by chart reviewers could also be low.15

Incident reporting systems are a popular mechanism that the majority of hospitals rely on to uncover internal threats to patient safety.1-4,20,21 Since IOM endorsed using incident reporting systems in its landmark report on patient safety, 27 states and the District of Columbia have established hospital AE reporting systems.13,22 Reporting systems include surveys of providers and structured interviews and can provide rich information about medical errors that lead to AEs. Incident reporting systems can identify latent errors (“system problems”) not uncovered by some other methods; thus, they can be used to improve patient safety.13,15,16 In comparison with comprehensive chart reviews, incident reporting is also relatively inexpensive.15

However, like other methods for detecting safety problems, incident reporting has its own limitations. Incident reporting systems alone cannot reliably measure incidence and prevalence rates of errors and AEs.20,23 Providers may not report errors because of busy schedules, concerns about potential lawsuits, fear their reputations could be tarnished, or misperceptions about what constitutes patient harm.20 As a result, reported incidents may represent only a portion of serious incidents and may misguide detailed investigation efforts to less important targets.16,18,20,23,24 Additionally, the rates of incidents reported over time may not reflect real changes in safety in an institution, because an increased rate may simply indicate an improved commitment by the institution to identify medical errors rather than a true rise in medical hazards.23

In recent years, with the adoption of electronic medical records, computerized surveillance, including using electronic triggers, has become an increasingly popular method for identifying certain types of medical errors or AEs, particularly those related to use of medications.25-28 By integrating multiple data sources (e.g., electronic medical records, laboratory, pharmacy, billing), computerized surveillance may efficiently detect medical errors and AEs and could provide real-time information for preventing harm to patients from errors in medical treatment.25-28 Use of electronic medical record-based surveillance of diagnostic errors was also reported.29 However, the accuracy and reliability of the tools for computerized surveillance need further study.30 The initial cost of the systems remains another barrier to implementation.25

Similarly, other methods for detecting and monitoring patient safety problems (e.g., chart audits assisted with trigger tools, direct observation of patient care, executive walk rounds, administrative data analysis, data warehouses) also have their strengths and weaknesses. We have identified several documents that provide an overview of these methods based on systematic or targeted literature review.14-16 Table 1 summarizes the purposes of different patient safety problem detecting methods. Tables 2 and 3 summarize the strengths and weaknesses of these methods. Because the original documents used different taxonomies for the methods, we compiled the adapted tables together in this chapter to provide a more comprehensive overview. As a result, some contents in these tables may overlap.

Table 1, Chapter 36 Overview of the purposes of different methods for detecting patient safety problems

Method | Adverse Event Counting (Frequency Assessment) | | Adverse Event Understanding (Root Cause Analysis) Latent Causes/Contributory Factors
Method | Harm | Active Errors | Adverse Event Understanding (Root Cause Analysis) Latent Causes/Contributory Factors
Review of medical records | X | X | ?
Studies based on interviews with health-care providers | X | X | X
Direct observation | X | X | X
Use of incident reporting systems | ? | ? | X
External audit and confidential inquiries | NR | NR | X
Studies of claims and complaints | NR | NR | X
Use of information technology and electronic medical records | X | NR | NR
Analysis of administrative data | X | NR | NR
Analysis of autopsy reports | X | NR | NR
Analysis of mortality and morbidity data | X | NR | X

Source: Michel P. 2003.^14^ Used with permission.

X Method is relevant for the purpose

? Relevance of the method for the purpose is to be confirmed

NR not relevant

Table 2, Chapter 36 Advantages and disadvantages of different methods used to measure errors and adverse events in health care (from the Thomas and Petersen study)

Method | Advantages | Disadvantages
Morbidity and mortality conferences and autopsy | - Can suggest latent errors; - Familiar to health care providers and required by accrediting groups | - Hindsight bias; - Reporting bias; - Focused on diagnostic errors; - Infrequently and nonrandomly utilized
Malpractice claims analysis | - Provides multiple perspectives (patients, providers, lawyers); - Can detect latent errors | - Hindsight bias; - Reporting bias; - Nonstandardized source of data
Error reporting systems | - Can detect latent errors; - Provide multiple perspectives over time; - Can be a part of routine operations | - Reporting bias; - Hindsight bias
Administrative data analysis | - Utilizes readily available data; - Inexpensive | - May rely upon incomplete and inaccurate data; - The data are divorced from clinical context
Chart review | - Utilizes readily available data; - Commonly used | - Judgments about adverse events not reliable; - Expensive; - Medical records are incomplete; - Hindsight bias
Electronic medical record | - Inexpensive after initial investment; - Monitors in real time; - Integrates multiple data sources | - Susceptible to programming and/or data entry errors; - Expensive to implement; - Not good for detecting latent errors
Observation of patient care | - Potentially accurate and precise; - Provides data otherwise unavailable; - Detects more active errors than other methods | - Expensive; - Difficult to train reliable observers; - Potential Hawthorne effect; - Potential concerns about confidentiality; - Possible to be overwhelmed with information; - Potential hindsight bias; - Not good for detecting latent errors
Clinical surveillance | - Potentially accurate and precise for adverse events | - Expensive; - Not good for detecting latent errors

Source: Thomas EJ and Petersen LA. 2003.^15^ Used with permission.

Table 3, Chapter 36 Advantages and disadvantages of different methods for hospitals to monitor for internal patient safety problems (from the Shojania study)

Method | Advantages | Disadvantages
Traditional incident reporting | - Process already ubiquitous; - Can identify latent errors (“system problems”) | - Underreporting of serious incidents; - Frequent reporting of events not suited to individual analysis (e.g., falls); - Can be demoralizing when staff do not perceive meaningful improvements resulting from incidents they have reported; - Cannot assess changes in safety (over time)
Stimulated/facilitated incident reporting | - Builds on an existing process; - Improves frequency of events and broadens range of events; - Can contribute to improvements in culture | - More labor intensive than traditional incident reporting; - Greater engagement of staff increases importance of making meaningful improvements (i.e., even more demoralizing than usual if improvements not made); - Cannot assess changes in safety
Patient complaints | - Process or data already exist; - Highlights important problems about patient experience often not captured elsewhere | - May be dismissed by clinicians as “service problems”; - May require more up-front work (compared with incident reporting) to identify incidents worth analyzing in detail for potential safety improvements; - Cannot assess changes in safety
Malpractice claims | - Process or data already exist; - Details about causes of the event and its impact on the patient usually collected as part of medicolegal process; - Complements incident reporting for capturing rare but serious events (e.g., wrong-site surgery) | - Heavily biased toward detecting diagnostic issues and procedural complication (though these are usually not detected by other systems); - Cannot assess changes in safety
Risk management reports | - Probably similar to malpractice claims, but not clear | - Probably similar to malpractice claims, but not clear
Executive walk rounds | - Engages frontline staff without requiring much work for them; - Provides a human face to problems management usually learns about through impersonal pie charts and time trends; - Alerts management to problems faced daily by frontline staff | - Demoralizing to frontline staff if management focuses only on improved public relations (“management cares”) and does not seriously address the problems identified; - Tempting for management to focus on easy fixes (e.g., related to equipment) not deeper problems or those requiring substantial investments of resources (e.g., staffing, skill mix, or work-load problems)
Chart audits (commonly operationalized with “trigger tools”) | - Types of events captured may be more likely to engage frontline clinicians (especially physicians); - Produce rates that can be monitored over time, not just counts or frequencies susceptible to changes in reporting biases | - Requires willing clinicians to participate; - Many important events not documented in charts and contributing factors for documented events typically unclear; - Many triggers have low specificity
Electronic triggers (e.g., drug-lab combinations, use of “antidotes” suggestive of medication errors) | - Very efficient; - Potentially high sensitivity capture for the events captured | - Captures only certain types of events (small subset of events involving medications or laboratory tests); - Trade-offs between sensitivity and specificity
Performance indicators derived from administrative data | - Data easily available; - In principle, event rates can be tracked over time, but in practice probably applies only for frequent event types in large health care systems | - Low signal-to-noise ratio; - Various methodologic problems leading to misleading characterizations of performance; - Managers and clinicians tend to distrust these data (often with good reason); - Requires intensive effort to investigate if poor performance is real and further effort to determine causes
Data warehouses | - Richness of detail (e.g., from medications data, laboratory results, time stamps) addresses many of the limitations of administrative data; - Can generate data that will engage both managers and clinicians; - Event rates can be followed over time | - Requires substantial up-front investments and appropriate clinical and methodological expertise; - Requires organizational culture and management structures conducive to driving change on the basis of these novel data
Modifying traditional morbidity and mortality rounds with modern patient safety framework | - Builds on format familiar to clinicians; - Types of events captured and richness of detail more likely to engage physicians | - Care required to avoid traditional focus on individual errors and blaming other departments; - New processes required to follow-up systematically on issues identified (traditional rounds heavy on discussion, with follow-up occurring only haphazardly); - Addressing problems identified often requires host department to engage and collaborate with other departments—departures from traditional norm
Discrepancies between clinical and autopsy diagnoses | - Builds on a traditional process of improvement; - Detects problems likely to engage clinicians | - Likely to succeed only in select hospitals because of low autopsy rates and decreased interest in autopsies among clinicians and pathologists at most hospitals
Monitoring pathologic discrepancies (e.g., between cytology and histology or antemortem biopsies and autopsies) | - Relatively efficient; - Can identify patterns of problems amenable to substantial improvement projects; - Event rates can be followed over time | - Requires interest on the part of pathologists to undertake this nontraditional form of quality assurance and willingness of clinical departments to collaborate in improvement projects
Corrected laboratory results/reports | - Relatively efficient; - Event rates can probably be followed over time | - Fairly narrow focus; - Requires interested laboratory medicine personnel
Natural language screening of electronic portions of medical records | - Relatively efficient once implemented; - Reasonable sensitivity and specificity for certain types of events | - Requires appropriate technical expertise and initial investment of time to develop and refine combinations of search terms with acceptable sensitivity and specificity for safety problems
Direct observation (e.g., audits of hand hygiene compliance, medication administration, operating room procedures daily rounds) | - Richer, more accurate data than by many other methods; - Identifies problems particularly difficult to detect by other means; - Event rates can be followed over time | - Somewhat labor intensive (but short periods of measurement may provide ample data); - Requires appropriately trained observers; - Care must be taken not to create mistrust among frontline staff
Active surveillance (combination of chart-based trigger tool applied in quasi-real time, stimulated reporting, and other interactions with frontline staff) | - Rich data that are more likely to include information about causal factors than record review alone; - Process can engage frontline staff and stimulate them to participate in subsequent improvement efforts; - Event rates can be followed over time | - Somewhat labor intensive (but short periods of measurement may provide ample data); - Requires appropriately trained observers; - Care must be taken not to create mistrust among frontline staff
Telephone calls to patients (can be automated) | - Identifies problems typically not captured by other methods (e.g., post-discharge adverse events and problems occurring between ambulatory visits) | - Requires appropriate technology and, even with automation, still requires investment of personnel time (e.g., at least one nurse case manager and a physician) to respond in real-time to clinical problems

Source: Shojania KG. 2010.^16^ Used with permission.

As Tables 2 and 3 have demonstrated, health care organizations have been using a wide array of methods to detect AEs and medical errors.14-19 Many of these methods (e.g., trigger tools) can be further categorized by the targeted problems (e.g., medication-related medical errors or iatrogenic infections), tools, algorithms, and data source used. Given the limited timeframe for this review, we focus this chapter on general approaches to detecting patient safety problems that involve using multiple methods (e.g., incident reporting, executive walk rounds, clinical surveillance, chart review, and trigger tools) to collect data.

We primarily reviewed studies that compared the utilities of different methods. However, comparison studies that used any method as a gold standard to validate another method were not included for this chapter, because, in essence, these studies still focused on one individual method (i.e., the method being validated). We believe that understanding the strengths and weaknesses of various methods is crucial for decisionmakers who need to form an effective strategy for monitoring patient safety problems that is appropriate for their organizations.

Readers who are seeking information on individual methods can refer to studies and reviews specifically focusing on those methods. As we reviewed the literature for this chapter, we identified a large number of publications focusing on individual methods, particularly in the areas of incident reporting, chart review, and trigger tools. Some systematic or targeted reviews provided insightful summaries about commonly used methods.13,18,22,31,32

## Why Should This Patient Safety Practice Work?

Detection of AEs is a primary step to achieving a safe health care system. In the report, “Safe Practices for Better Healthcare—2010 Update,” the National Quality Forum stated that health care organizations must systematically identify and mitigate patient safety risks and hazards with an integrated approach to continuously drive down rates of preventable patient harm.33 As several landmark studies have suggested, medical errors are often a system failure where care practices are inconsistent among health care professionals.6,34,35 By systematically uncovering these errors and analyzing their causes, health care institutions can identify defects in processes of care and design system changes to prevent the errors.18,19,23

In the 1999 report, “To Err is Human: Building a Safer Health Care System,” the IOM also acknowledged the need to learn from medical errors and recommended establishing mandatory incident reporting systems as part of an approach to improving safety.6 The report noted that one of the causes of medical errors is lack of reliable data on the number of medical errors, which limits the ability to identify the problem's origins and develop initiatives to resolve the problem. A subsequent IOM report, “Crossing the Quality Chasm: A New Health System for the 21^st^ Century,” reinforced the need for reliable data and noted a need for evidence-based policies and practices.36 By performing root-cause analyses (an in-depth examination of the data to identify factors in the care process that contribute to the errors) and implementing corrective action plans, health care organizations may be able to address system and process failures to ensure that potential errors are prevented in the future.5,7,22,23

## What Are the Beneficial Effects of the Patient Safety Practice?

Measuring the beneficial effects of a safety-problem detection approach is not always straightforward. Few studies have measured changes in health outcomes that are brought about by implementing a safety-problem detection method. Designing rigorous studies to establish a direct connection between the method and any patient safety outcomes is challenging. The effectiveness, if any, of a safety-problem detection method may not always translate into better patient outcomes. These outcomes rely not only on how promptly and accurately the problems are identified but also on how the safety data are used in root-cause analyses and whether the corrective action plans are implemented effectively.5,6,22,23,36 If the safety data were misinterpreted or the action plans were not executed successfully, no improvement in safety outcomes would be observed regardless of the effectiveness of the detection method per se.6,22

Additionally, accurately estimating the true prevalence of safety problems is almost impossible, particularly with medical errors that did not cause any harm.23 While chart review has been used as the gold standard in some patient safety studies to quantify AE rates, it rarely detects medical errors that produce no harm and may also miss other safety problems because of incomplete documentation in the medical record.15,16 When an increased number of medical errors is identified, determining whether the finding reflects a deteriorating performance in risk management or is the result of improved efforts in uncovering these errors is difficult. Likewise, a decreased number of detected safety problems could be the result of effective risk management or simply reflect inadequate efforts to find the problems.

Because of these reasons, empirically measuring the impacts of safety-problem detection methods on patient outcomes is almost unlikely. The beneficial effects of these detection methods have often been judged partly on data and partly on assumptions. If data suggest that a method helped detect medical errors that had not been found via other means or detected more errors in a more timely fashion than other mechanisms, the method would be assumed beneficial to patient safety. While these assumptions appear reasonable, the data do not provide direct evidence that the detection method will lead to improved patient safety outcomes.

As discussed, we primarily reviewed studies that compared the utility of different methods. Our search identified one systematic review published by the World Health Organization (WHO) in December 2003.^14^ This study by Michel reviewed methods for assessing the nature and scale of harm caused by health systems. The objective of the study was to identify the strengths and weaknesses of available methods according to a defined set of criteria. These criteria included the following:14

- Effectiveness in capturing the extent of harm (in different environments).
- Availability of reliable data (judged by interobserver reliability).
- Suitability for large-scale or small, repeated studies. (Large-scale studies refer to national and regional studies. Small, repeated studies are carried out for a limited period at the hospital or local level.)
- Costs (financial, human resources, time, and burden on system).
- Effectiveness in influencing policy (focused on national, regional, or local policy or strategic programs).
- Effectiveness in influencing hospital and local safety procedures and outcomes.
- Synergy with other domains of quality of care.

This set of criteria was defined by the WHO Working Group in “Patient Safety: Rapid Assessment Methods for Assessing Hazards” in December 2002. The first four criteria focused on the intrinsic characteristics of the methods, their validity, reliability, and cost. The last three criteria were more related to the ability of the methods to trigger improvements in safety cultures and the quality of safety programs. The study reviewed 262 relevant studies. With the exception of comparative studies available for the assessment of effectiveness in capturing the extent of harm, the literature consisted mostly of descriptive studies. For the review, Michel considered the data reported in the included studies as well as the opinions of the authors of the studies.

The study rated each method on all seven criteria to produce a summary of its key strengths and limitations.14 When valid information was available, the author rated the criteria from 1 (least favorable) to 4 (most favorable). A study was defined as “valid” when an appropriate description of the method (sampling strategy, data collection, and data analysis) in line with “current standards” was available. The lowest level (1) indicates low effectiveness, suitability, or availability, or it means very high cost. Where the amount of evidence-based data was small, the author noted “to be confirmed.” The evidence-based ratings for each method in the seven areas are provided in Table 4. In the absence of valid data, the author used a subjective rating scale from 1 (least favorable) to 4 (most favorable), based on the opinions of the studies being reviewed. These opinion-based ratings are provided in Table 5. Both Table 4 and Table 5 were based on literature from developed countries. The author also reviewed literature from developing countries, but that information is not discussed in this chapter.

Table 4, Chapter 36 Evidence-based rating of the main methods used in developed countries for estimating hazards in health care systems

| Ad Hoc Studies Based on Epidemiological Designs and Systematic Data Collection | | | Methods Based on Reporting | | Analysis of Routinely Collected and Existing Data
Criteria | Review of Medical Records | Studies Based on Interviews With Health-Care Providers | Direct Observation | Incident Reporting Systems | External Audit and Confidential Inquiries | Studies of Claims and Complaints | Electronic Medical Records | Administrative Data | Autopsy Reports | Mortality and Morbidity Conferences
Effectiveness in capturing the extent of harm | 4 | 4 | No evidence available | 2 | No evidence available | 2 | 3 | 2 | 2 | 2, to be confirmed^*^
Availability of reliable data | 2 | 4 for harm assessment, to be confirmed^*^ | No evidence available | No evidence available | No evidence available | 3 | No evidence available | 2 | 3, to be confirmed^*^ | No evidence available
Suitability for large-scale studies | 3 | 3, to be confirmed^*^ | No evidence available | 4 | 3 | 3 | 2 | 4, to be confirmed^*^ | 1 | 4
Suitability for small, repeated studies | 3 | 3 | No evidence available | 4 | Not applicable | 4 | 4 | 4, to be confirmed^*^ | No evidence available | 4
Costs | 1 | 1 for prospective; 2 for cross-sectional | No evidence available | 3 | No evidence available | 4 | 3 | 4 | No evidence available | 4
Effectiveness in influencing policy | 3 | No evidence available | No evidence available | 3 | 3, to be confirmed^*^ | 3, to be confirmed^*^ | No evidence available | No evidence available | No evidence available | 4
Effectiveness in influencing hospital and local safety procedures and outcomes | 3 | No evidence available | No evidence available | 3, to be confirmed^*^ | No evidence available | 3, to be confirmed^*^ | 4 | 3, to be confirmed^*^ | No evidence available | 3, to be confirmed^*^
Synergy with other domains of quality of care | 4 | 4 | 4 | 2 | No evidence available | 3 | 4 | 4 | No evidence available | 4

Adapted from Michel P. Strengths and weaknesses of available methods for assessing the nature and scale of harm caused by the health system.14

Rating scale from 1 to 4, the most favorable level being 4

* “to be confirmed”— where the amount of evidence-based data is small

Table 5, Chapter 36 Subjective rating, where there was no evidence-based data, of the main methods used in developed countries for estimating hazards in health care systems

| Ad Hoc Studies Based on Epidemiological Designs and Systematic Data Collection | | | Methods Based on Reporting | | Analysis of Routinely Collected and Existing Data
Criteria | Review of Medical Records | Studies Based on Interviews With Health-Care Providers | Direct Observation | Incident Reporting Systems | External Audit and Confidential Inquiries | Studies of Claims and Complaints | Electronic Medical Records | Administrative Data | Autopsy Reports | Mortality and Morbidity Conferences
Effectiveness in capturing the extent of harm | * | * | 4 | * | 2 | * | * | * | * | *
Availability of reliable data | * | 1-2 for cause analysis | 4 for harm assessment, 2-3 for cause analysis | 2-3 | 2-3 | * | 2 | * | * | 3-4
Suitability for large-scale studies | * | * | 1 for global assessment, 3 for limited focus | * | * | * | * | * | * | *
Suitability for small, repeated studies | * | * | 2-3 (videotaping) | * | Not applicable | * | * | * | 3 | *
Costs | * | * | 1 | * | 1-2 | * | * | * | 3-4 | *
Effectiveness in influencing policy | * | 3-4 | 3-4 | * | * | * | 3-4 | 3-4 | | *
Effectiveness in influencing hospital and local safety procedures and outcomes | * | 2-3 | 3-4 | * | 1-2 | * | * | * | 2 | *
Synergy with other domains of quality of care | * | * | * | * | 2-4 | * | * | * | 1 | *

Adapted from Michel P. Strengths and weaknesses of available methods for assessing the nature and scale of harm caused by the health system.14

Rating scale from 1 to 4, the most favorable level being 4

* Evidence-based rating is available (see Table 4)

The WHO study revealed that the methods for assessing the nature and scale of harm caused by health systems have different purposes (Table 1), strengths, and limitations (Table 4 and Table 5).14 The main conclusion of the study was that these methods do not compete with each other. Instead, they complement each other by providing different levels of qualitative and quantitative information. The list of methods and the illustrative ratings (Table 4 and Table 5) provided by the study may serve as a starting point for choosing appropriate methods for detecting harms caused by health organizations. The author suggested that identification of appropriate methods must take into account the distinct environmental factors faced by each health care organization or region.

This WHO study also had limitations.14 First, the studies included for review varied in quality and quantity. For some methods of interest, such as interviews with health care providers, analysis of administrative data, or confidential inquiries, few studies were available for review. Some other methods that the author thought might be useful for detecting safety problems, such as single case analysis and focus group discussions, were not covered by the study. Second, the rating systems and criteria used in the study for judging the strengths or weaknesses of the methods were not adequately validated. The assessment of the methods was generally subjective rather than objective. Third, because of the wide variety of studies reviewed, the author was not able to use explicit criteria for quality assessment of the studies.

In addition to the WHO review, we also identified several primary studies that compared the utility of various methods for monitoring AEs or medical errors. In 2007, Olsen and colleagues compared the use of incident reporting, pharmacist surveillance, and local real-time record review for the recognition of clinical risks associated with hospital inpatient care.37 Using the three methods, they prospectively collected data on AEs on 288 patients discharged from an 850-bed general hospital in the National Health System in the UK. The study found little overlap in the nature of events detected by the three methods. Record review detected 26 AEs and 40 potential AEs (PAEs) occurring during the index admission. Incident reporting detected 11 PAEs and no AEs. Pharmacy surveillance found 10 medication errors, all of which were PAEs. The study concluded that incident reporting does not provide an adequate assessment of clinical AEs and that a variety of methods need to be used to provide a full picture of the safety condition in a health care organization.

In 2008, Wetzels and colleagues compared the validity and usefulness of five methods for identifying AEs in general practice.38 The five methods included physician reported AEs, pharmacist reported AEs, patients' experiences of AEs, assessment of a random sample of medical records, and assessment of all patients who died. In this prospective observational study, a total of 68 events were identified using these methods. The patient survey identified the highest number of events and the pharmacist reports identified the fewest. No overlap among the methods was detected. The authors concluded that a mix of methods is needed to identify AEs in general practice.

A study by Ferranti and colleagues compared results from two adverse drug event (ADE) detection methods—voluntary reporting and computerized surveillance—at a large academic medical center.39 This 2008 study analyzed the medications most likely to cause harm and evaluated the strengths and weaknesses of each detection system. During a 7-month period, computerized surveillance detected 710 ADEs (6.93/1,000 patient days), whereas voluntary reporting identified 205 ADEs (1.96/1,000 patient days). For each major drug category (anticoagulants, hypoglycemia, narcotics and benzodiazepines, and miscellaneous), the two methods detected significantly different event rates.39 Most surveillance-identified events were hypoglycemia-related, whereas most voluntarily-reported events were in the miscellaneous category. Of all unique ADEs (875), only 40 were common between the systems. The study's findings underscored the synergistic nature of the two ADE detection approaches. Although surveillance provides quantitative data to estimate the actual rate of ADEs, voluntary reporting contributes qualitative evidence to prompt future surveillance rule development and identify areas of emerging risk. The authors concluded that the two detection methods should be used together to provide a full picture of ADE-related patient safety problems.

In 2010, Levtzion-Korach and colleagues published a study that examined and compared five AE detection methods in one hospital.40 The methods included a Web-based voluntary incident reporting system, medical malpractice claims, patient complaints, the hospital risk management database, and executive walk rounds. These methods varied in the timing of the reporting (retrospective or prospective), severity of the events, and profession of the reporters. The five disparate data sources at the hospital captured about 15,000 problems. The authors systematically classified the detected problems into 23 categories using a taxonomy that they developed. The study found that each method identified important safety problems that were generally not captured by any of the other methods.40 The following are the common categories of safety problems detected using the five methods compared in the study:

- Spontaneous reporting: patient identification issues, falls, and medication problems
- Malpractice claims: issues with clinical judgment related to diagnosis and treatment, communication, and technical skills and problems with medical records (incomplete, illegible, or missing)
- Patient complaints: issues with communication, ancillary services (e.g., patient transport, kitchen, housekeeping), and administration (admission and discharge processes, scheduling)
- Risk management: issues with technical skills, patient and family behavior (compliance issues, unusual behavior by a patient or family members), administration, and clinical judgment
- Executive walk rounds: problems with equipment, electronic medical records and other such technologies, and infrastructure (work environment, security)

Communication problems were common among patient complaints and malpractice claims. Clinical judgment problems were the leading category for malpractice claims. Walk rounds identified issues with equipment and supplies. AE reporting systems highlighted identification issues, especially mislabeled specimens. The authors concluded that, to obtain a comprehensive picture of their patient safety problems and to develop priorities for improving safety, hospitals should use a broad portfolio of approaches and then synthesize the messages from all individual approaches into a collated and cohesive whole.

In another 2010 study, the Office of Inspector General of the Department of Health and Human Services compared the usefulness of five safety event screening methods: nurse reviews, analysis of present-on-admission (POA) indicators, Medicare beneficiary interviews, hospital incident reports, and analysis of patient safety indicators.41 The study used a sample of 278 Medicare beneficiary hospitalizations selected from all Medicare discharges from acute care hospitals in two selected counties during a 1-week period in August 2008. The investigators compared events flagged by each screening method to the 120 events identified and/or confirmed through physician reviews. The study found that nurse reviews and POA analysis identified the greatest number of safety events. Nurse reviews identified 93 of the 120 confirmed safety events and POA analysis identified 61 events. Beneficiary interviews identified 22 events, and the remaining two screening methods identified 8 events each. Of the 120 events, 55 (46%) were identified by only one screening method. Nurse reviews identified 35 events (29% of the 120 events) not flagged by any other screening method. POA analysis alone flagged 14 events (12% of the 120 events).

We also reviewed a study by Tinoco and colleagues that compared a computerized surveillance system (CSS) with manual chart review (MCR) for detecting inpatient ADEs and hospital-associated infections (HAIs).25 The authors retrospectively analyzed the events detected using the two methods by type of events. From a sample of 2,137 patient admissions between October 2000 and December 2001, the authors identified AEs that were detected only by MCR, only by CSS, or by both methods. The study found that CSS detected more HAIs than MCR (92% vs. 34%); however, a similar number of ADEs was detected by both systems (52% vs. 51%). The agreement between systems was 26 percent and 3 percent for HAIs and ADEs respectively. The study also found that MCR detected events missed by CSS using information in physician narratives and that some events found by MCR were missed by CSS. The authors concluded that integrating information from physician narratives with CSS using natural language processing would improve the detection of ADEs more than HAIs.

A compelling theme emerged among the findings of the studies reviewed for this section. That is, different methods for detecting patient safety problems overlap very little in the safety problems they detect. These methods complement each other and should be used in combination to provide a comprehensive safety picture of the health care organization. Detailed information on the studies reviewed in this section (except for the WHO report14) is provided in Appendix D. Because the body of evidence consists of studies of different designs, the overall strength of evidence is not assessed.

## What Are the Harms of the Patient Safety Practice?

None of the studies that we reviewed reported any harm directly caused by the implementation of a method for monitoring patient safety problems. However, in theory, a method that often fails to capture important AEs or medical errors may mislead the health care organization about its true safety status and cause a delay in addressing safety problems, likely leading to patient harms. Additionally, various detection methods may compete with each other for the limited resources available for risk management in an organization. Adopting a relatively ineffective method might shift resources from more effective alternatives and, thus, decrease the organization's overall performance in uncovering safety problems. This loss of detection capability, in turn, could lead to an increase in harms to the patients treated in the organization. However, designing rigorous studies to empirically test these hypotheses is difficult.

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

As previously described, a wide variety of methods exist for detecting patient safety problems, and this chapter focuses on evidence only from studies that compared these methods. The methods being compared were implemented differently due to their differences in the primary problems targeted, tools used, resources required, staff involved, and the timing (retrospective or “real-time”) of the detection (see Appendix D, the “Description of PSP” column).14-19

Some of these methods (e.g., incident reporting and trigger tools) can be further categorized (e.g., mandatory or voluntary incident reporting systems), and each method in the subcategories can also be implemented differently. For example, at least 27 states and some Government agencies (e.g., the U.S. Food and Drug Administration) in the U.S. have established some form of incident reporting systems. These various incident reporting systems or programs could be implemented differently in terms of data collected, tools used, reporting process, and how data are shared or used.1,2,13,18,21,22

Similarly, many different types of trigger tools and automated systems exist.31,32 These tools or systems target different problems (e.g., general AEs, ADEs, nosocomial infection, decubitus ulcers, surgical complications) and may involve different data sources, equipment, software, or algorithms. It is not feasible for this chapter to cover the implementation issues for all these methods. Therefore, we describe only the relevant information reported in the comparison studies reviewed for this chapter. This information is provided in Appendix D (refer to the “Description of PSP” and the “Context” columns).

## Are There Any Data About Costs?

Accurately estimating the cost associated with implementing strategies for detecting patient safety problems is difficult. The direct cost for this activity may include expenditures for equipment and materials (e.g., computers, software, photocopy machines, paper), facilities and space, and labor for collecting and analyzing data. Indirect, overhead expenses also may need to be counted. These direct and indirect costs vary across health care organizations and regions and constantly change over time.

Our search identified sporadic data about costs for implementing safety problem detection methods. The most recent and relevant data came from the study by Levtzion-Korach.40 This study estimated the direct cost of the five methods used in one hospital (Table 6). It showed that the hospital's expenditures on these systems were estimated to be a one-time cost of $120,000 and an annual cost of almost $1 million. Additionally, we identified some general discussions about which detection methods are generally more expensive or labor-intensive (Table 2 and Table 3). Our search did not identify any full economic evaluation (e.g., cost-effectiveness analysis from the public's perspective) of the burden related to the implementation of various methods for detecting AEs or medical errors.

Table 6, Chapter 36 Estimated costs of systems for detecting patient safety problems in one hospital

| Incident Reporting | Patient Complaints | Risk Management | Malpractice Claims | Executive Walk Round
Software
One-time expense | $72,400 | $42,580 | $0 | Not directly supported by the institution | $0
Annual support | $9,000 | $3,395 | $0 | Not directly supported by the institution | $0
Manpower
Annual support | 0.5 FTE PS manager: $43,340 0.2 FTE RM analyst: $18,000 0.1 FTE PS analyst: $4,500 | 12 FTE PS analyst: $540,000 | 3.5 FTE risk management analyst: $318,500 | Not directly supported by the institution | 0.2 FTE PS manager: $17,380 0.3 FTE PS analyst: $12,780 A weekly hour of CEO, CMO, CNO, and COO: $10,500
Sum
One-time expense | $72,400 | $42,580 | $0 | Not directly supported by the institution | $0
Annual support | $74,840 | $543,395 | $318,500 | Not directly supported by the institution | $40,660

Source: Levtzion-Korach O. et al. 2010.^40^ Used with permission.

Abbreviations: FTE PS=full-time equivalent patient safety; FTE RM=full-time equivalent risk management; CEO=chief executive officer; CMO=chief medical officer; CNO=chief nursing officer; COO=chief operating officer.

## Are There Any Data About the Effect of Context on Effectiveness?

For this chapter, we focus on the evidence only from studies that compared different methods for detecting patient safety problems. It is not feasible for the chapter to review the effect of context on effectiveness for each individual method. We collected data only on the context for the methods being compared in the included studies. These data fall into five categories: the external context, organizational characteristics, teamwork, leadership, and culture (see Appendix D, the “Context” column). However, based on the data collected, no conclusion can be drawn regarding the effect of context on the effectiveness of the detection methods, mainly because these studies were not designed to assess such links.

Nevertheless, the importance of strong leadership, teamwork, and organization-wide safety culture to successful implementation of patient safety practices as a whole has been well documented in literature that is beyond the scope of this chapter.3,6,22,23 It is reasonable to expect that leadership, teamwork, and safety culture have the same impact on the implementation of patient safety monitoring strategies. Additionally, the external factors (e.g., how governments or the Joint Commissions use the safety data reported by hospitals) should also have a significant impact on the effectiveness of the strategies.13,18,21

## Conclusions and Comment

The studies reviewed for this chapter consistently suggested that each method for detecting AEs or medical errors has advantages and disadvantages. These various methods do not compete with each other. They identify fairly distinct problems and complement each other by providing different levels of qualitative and quantitative information about patient safety.

Health care organizations are generally faced with a variety of safety problems, such as misdiagnoses, misidentified patients, falls, procedural complications, and medication-related errors. All these problems need to be identified adequately so that hospitals can effectively prioritize the problems on the basis of the burden of harm and costs associated with the problems, the availability of effective prevention strategies, and the likelihood of local success in implementing such strategies.3,6,22,23 Therefore, health care organizations should use a broad portfolio of methods to uncover safety problems and then synthesize the data collected into a comprehensive picture.40

For administrators and risk management professionals, a primary challenge is how to make a rational choice among a large number of methods to build a portfolio appropriate for their organizations.40 While no simple formula exists to guide the decisionmaking process, the composition of the portfolio generally depends on the safety problems most relevant to the organization and the resources available for the risk management effort.16 The bottom line is that the choice of a specific method by a health care organization might not be as important as the decision to use more than one method.16 The information that we compiled in this chapter is intended to serve as a starting point for health care organizations to reconsider their general approach to monitoring patient safety problems. Future research needs to assess the effectiveness of different portfolios of methods and provide practical guidance on how to combine the information collected using different methods into one safety picture. A summary table is located below (Table 7).

Table 7, Chapter 36 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Low-to-High | Low | Negligible | High | Moderate/Difficult

## References

1 Indiana medical error reporting system: report for 2009. Indianapolis (IN). Indiana State Department of Health. Aug. 30. 2010:56. www.in.gov/isdh/files/2009_MERS_Report.pdf.
2 Utah Department of Health, HealthInsight, UHA, Utah Hospitals & Health Systems Association. 2009 Utah Sentinel events data report: identifying opportunities for improvement. Utah. Utah Department of Health;. Mar. 2010:9. http://health.utah.gov/psi/pubs/sentinel_events09.pdf.
3 Adverse health care events reporting system: what have we learned?. St. Paul (MN). Minnesota Department of Health. 2009. Jan. 32 p.
4 Thompson WC Jr. The high costs of weak compliance with the New York State hospital adverse event reporting and tracking system: policy report. New York (NY). New York State Department of Health. Mar. 9. 2009:54. www.comptroller.nyc.gov.
5 Zegers M, de Bruijne MC, de Keizer B, et al. The incidence, root-causes, and outcomes of adverse events in surgical units: implication for potential prevention strategies. Patient Saf Surg. 2011;5:13. www.ncbi.nlm.nih.gov/pmc/articles/PMC3127749/pdf/1754-9493-5-13.pdf. [pmid: 21599915].
6 Institute of Medicine Committee on Quality of Health Care in America, Kohn LT, Corrigan JM, Donaldson MS, editors. To err is human: building a safer health system. Washington (DC). National Academy Press. 1999. Nov. 1. 223 p. http://stills.nap.edu/books/0309068371/html.
7 Wachter RM. Patient safety at ten: unmistakable progress troubling gaps. Health Aff (Millwood). Jan-Feb. 2010;29(1):165-73. http://content.healthaffairs.org/content/29/1/165.full.pdf. [pmid: 19952010].
8 Leape LL, Berwick DM. Five years after To Err Is Human: what have we learned. JAMA. May. 18. 2005;293(19):2384-90. [pmid: 15900009].
9 Altman DE, Clancy C, Blendon RJ. Improving patient safety--five years after the IOM report. N Engl J Med. Dec. 11. 2004;351(20):2041-3. [pmid: 15537902].
10 Lucado J, Paez K, Elixhauser A. Medication-related adverse outcomes in U.S. hospitals and emergency departments, 2008: statistical brief #10 [internet]. Rockville (MD). Agency for Healthcare Research and Quality (US). 2011. Apr. 2011 Sep 13. [pmid: 21595139].
11 Institute for Healthcare Improvement. Protecting 5 million lives from harm. [internet]. Cambridge (MA). Institute for Healthcare Improvement. 2011 Nov 10.
12 National Quality Forum (NQF). NQF patient safety terms and definitions. Washington (DC). National Quality Forum (NQF). 2009. Dec. 6 p. www.qualityforum.org/Topics/Safety_Definitions.aspx.
13 Office of Inspector General. Adverse events in hospitals: state reporting systems. Washington (DC). Department of Health and Human Services. Dec. 2008:37. http://oig.hhs.gov/oei/reports/oei-06-07-00471.pdf.
14 Michel P. Strengths and weaknesses of available methods for assessing the nature and scale of harm caused by the health system: literature review. Geneva. World Health Organization (WHO). 2003. 59 p. www.who.int/patientsafety/research/P_Michel_Report_Final_version.pdf.
15 Thomas EJ, Petersen LA. Measuring errors and adverse events in health care. J Gen Intern Med. Jan. 2003;18(1):61-7. [pmid: 12534766].
16 Shojania KG. The elephant of patient safety: what you see depends on how you look. Jt Comm J Qual Patient Saf. Sep. 2010;36(9):399-401. [pmid: 20873672].
17 Michel P, Quenon JL, de Sarasqueta AM, et al. Comparison of three methods for estimating rates of adverse events and rates of preventable adverse events in acute care hospitals. BMJ. Jan. 24. 2004;328(7433):199. [pmid: 14739187].
18 World Alliance for Patient Safety. WHO draft guidelines for adverse event reporting and learning systems. Geneva (Switzerland). World Health Organization. 2005. 80 p. www.who.int/patientsafety/events/05/Reporting_Guidelines.pdf.
19 Leape LL. Reporting of adverse events. N Engl J Med. Nov. 14. 2002;347(20):1633-8. [pmid: 12432059].
20 Levinson DR. Hospital incident reporting systems do not capture most patient harm [OEI-06-09-00091]. Washington (DC). Department of Health and Human Services, Office of Inspector General. 2012. Jan. 42 p.
21 United States Government Accountability Office. Health-care-associated infections in hospitals: an overview of state reporting programs and individual hospital initiatives to reduce certain infections. Washington (DC). United States Government Accountability Office. Sep. 2008:55. www.gao.gov/products/GAO-08-808.
22 The power of safety: state reporting provides lessons in reducing harm, improving care. [internet]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2010. 2011 Jul 27. [2 p]. http://psnet.ahrq.gov/resource.aspx?resourceID=18516.
23 Shojania KG, Duncan BW, McDonald KM, et al. Making health care safer: a critical analysis of patient safety practices. AHRQ. 2001;(43):i-x. 1. 668.
24 Brunicardi FC, Heggeness MH, Andersen DK, et al. Orthopedic surgery. Schwartz's principles of surgery [database online]. 9th. New York (NY). McGraw-Hill Companies, Inc. 2010. 2011 May 26. [2 p]. www.accessmedicine.com/content.aspx?aID==5028211.
25 Tinoco A, Evans RS, Staes CJ, et al. Comparison of computerized surveillance and manual chart review for adverse events. J Am Med Inform Assoc. Jul-Aug. 2011;18(4):491-7. [pmid: 21672911].
26 Kilbridge PM, Noirot LA, Reichley RM, et al. Computerized surveillance for adverse drug events in a pediatric hospital. J Am Med Inform Assoc. Sep-Oct. 2009;16(5):607-12. [pmid: 19567791].
27 Ferranti J, Horvath MM, Cozart H, et al. Reevaluating the safety profile of pediatrics: a comparison of computerized adverse drug event surveillance and voluntary reporting in the pediatric environment. Pediatrics. May. 2008;121(5):e1201-7. [pmid: 18450863].
28 Rommers MK, Teepe-Twiss IM, Guchelaar HJ. A computerized adverse drug event alerting system using clinical rules: a retrospective and prospective comparison with conventional medication surveillance in the Netherlands. Drug Saf. Mar. 1. 2011;34(3):233-42. [pmid: 21332247].
29 Singh H, Giardina TD, Forjuoh SN, et al. Electronic health record-based surveillance of diagnostic errors in primary care. BMJ Qual Saf. Feb. 2012;21(2):93-100. http://qualitysafety.bmj.com/content/21/2/93.full.pdf. [pmid: 21997348].
30 Murff HJ, FitzHenry F, Matheny ME, et al. Automated identification of postoperative complications within an electronic medical record using natural language processing. JAMA. Aug. 24. 2011;306(8):848-55. [pmid: 21862746].
31 Triggers and targeted injury detection systems (TIDS) expert panel meeting: conference summary. [AHRQ Publication No. 090003]. Agency for Healthcare Research and Quality. Jun. 30. Jul. 1. Rockville (MD). Agency for Healthcare Research and Quality, U. S. Department of Health and Human Services. 2009 Feb. 2008:1-57. www.ahrq.gov/qual/triggers/.
32 Govindan M, Van Citters AD, Nelson EC, et al. Automated detection of harm in healthcare with information technology: a systematic review. Qual Saf Health Care. Oct. 2010;19(5):e11. [pmid: 20671081].
33 National Quality Forum. Safe practices for better healthcare 2010 update, a consensus report. [internet]. Washington (DC). National Quality Forum. 2010. Apr. 2011 Nov 10. [54 p]. www.qualityforum.org/Publications/2010/04/Safe_Practices_for_Better_Healthcare_%e2%80%93_2010_Update.aspx.
34 Reason J. Understanding adverse events: human factors. Qual Health Care. Jun. 1995;4(2):80-9. [pmid: 10151618].
35 Vincent C. Understanding and responding to adverse events. N Engl J Med. Mar. 13. 2003;348(11):1051-6. [pmid: 12637617].
36 Institute of Medicine, Committee on Quality of Health Care in America, Corrigan JM, et al., editors. Crossing the quality chasm: a new health system for the 21st century. Washington (DC). National Academy Press. 2001. 337 p. http://search.nap.edu/books/0309072808/html/.
37 Olsen S, Neale G, Schwab K, et al. Hospital staff should use more than one method to detect adverse events and potential adverse events: incident reporting, pharmacist surveillance and local real-time record review may all have a place. Qual Saf Health Care. Feb. 2007;16(1):40-4. www.ncbi.nlm.nih.gov/pmc/articles/PMC2464933/pdf/40.pdf. [pmid: 17301203].
38 Wetzels R, Wolters R, van Weel C, et al. Mix of methods is needed to identify adverse events in general practice: a prospective observational study. BMC Fam Pract. 2008;9:35. [pmid: 18554418].
39 Ferranti J, Horvath MM, Cozart H, et al. A multifaceted approach to safety: the synergistic detection of adverse drug events in adult inpatients. J Patient Saf. 2008;4:184-90. http://analytics.dhts.duke.edu/wysiwyg/downloads/Ferranti_JPS_adults.pdf.
40 Van Der Linden W, Warg A, Nordin P. National register study of operating time and outcome in hernia repair. Arch Surg. Oct. 2011;146(10):1198-203. [pmid: 22006880].
41 Levinson DR. Adverse events in hospitals: methods for indentifying events [OEI-06-08-00221]. Washington (DC). Department of Health and Human Services, Office of Inspector General. 2010. Mar. 60 p.