# Promoting a Culture of Safety

## How Important Is the Problem?

A culture of safety has been suggested as a core mechanism underlying safe, effective, and timely patient care. It has been implicated as a critical factor underlying continuous learning and effective teamwork, as well as a key driver of safety behaviors such as error reporting, and safety outcomes such as reduced adverse events.1,2

A number of studies have found associations between culture and safe care practices, such as error reporting1,3-5 Other studies have found associations between patient safety culture and patient outcomes, including reduced adverse event indicies6 and mortality.7,8 For example, several studies have found relationships between safety culture and the AHRQ Patient Safety Indicators.9,10 In one study that utilized a composite of 12 AHRQ patient safety indicators results suggested that a 1 standard deviation increase in patient safety culture scores was associated with a 10% decrease in the composite PSI risk.10 Other work has indicated that culture can account for up to 6% of the variance in adverse events and 18% of the variance in patient willingness to recommend a hospital to family and friends.11

## What Is the Patient Safety Practice?

Compared with other patient safety practices, interventions to promote patient safety culture (PSC) are less easily defined. Effective safety cultures have been described as those in which there is shared commitment to safety as the highest priority, where engaging in safety-promoting behaviors is encouraged and reinforced by leaders and peers, and where glitches or near misses are valued as opportunities for learning and improvement. Therefore, interventions to promote safety culture include a broad range of interventions rooted in principles of promoting leadership, creating effective teamwork, and behavior change rather than a single specific process, team, or technology. For example, interdisciplinary rounding12,13 and executive walkrounds,14,15 as well as interventions designed to enhance provider communication,16 to encourage error reporting,14,17 and team training18,19 have all been labeled as interventions “to promote a culture of safety.” In the present review, for example, 11 studies described multi-faceted interventions (i.e., interventions or practices with multiple components or aspects).13,14,16,19-26

Precise definition is further complicated given that few patient safety interventions are implemented with the sole primary goal of promoting safety culture. For example, it is relatively common for another PSP, such as a Rapid Response System (RRS), to be implemented with the primary goal of reducing code events or other negative patient outcomes. Promoting a culture of safety may be a secondary goal of an RRS intervention, and data regarding the change in staff perceptions of safety culture following implementation of the RRT intervention may be reported; however, improving safety culture was not the primary stated goal of the intervention. In this sense, some studies treat safety culture as a primary outcome variable, while others treat it as a contextual variable that may moderate the efficacy of another PSP.

This review is specifically focused on studies in which the primary intervention goal was explicitly to promote a culture of safety. We did not limit inclusion criteria based on a particular type of intervention with the aim of identifying the full breadth of different practices being described as interventions to promote safety culture.

## Why Should This Patient Safety Practice Work?

Patient safety culture (PSC) is defined as a holistic snapshot of enacted norms, policies, and procedures related to patient safety that guide the behaviors, attitudes, and cognitions of care providers.27 In this sense, PSC is a social aspect of the work environment that shapes what provides do, think, and feel during their day-to-day work activities. More concretely, PSC has been described as a shared commitment to patient safety as the most important organizational goal that provides cues to clinicians and staff about the relative priority of patient safety in comparison to other unit or organizational goals. In this way, working in strong, positive safety cultures motivates employees to behave in ways that support safety. In such work environments, clinicians and employees feel a sense of obligation to speak up if they see a potential hazard, to lend a hand to fellow team members, to ask for help if they need it, and believe that putting patient safety first will be recognized and rewarded. Given its role as a motivational force that helps to shape clinician behaviors and attitudes, and cognitions, PSC is important for understanding issues of safety, care quality, error, and process improvement.

PSC is a facet-specific form of general organizational culture, meaning that is a specific form of organizational culture that focuses on a narrowly defined aspect of performance, namely patient safety. For example, general organizational culture refers to:

a pattern of shared basic assumptions learned by a group as it solved problems…which have worked well enough to be considered valid and, therefore, to be taught to new members as the correct way to perceive, think, and feel…28

PSC therefore refers to the pattern of assumptions shared among members of a group (e.g., a unit or organization) specifically related to patient safety and can be differentiated from general organizational culture.29,30 More specifically, Sorra and Nieva31 cite the following the definition of safety culture in their work dedicated to measuring patient safety culture:

the product of individual and group values, attitudes, perceptions, competencies, and patterns of behavior that determine the commitment to, and the style and proficiency of, an organization's health and safety management. Organizations with a positive safety culture are characterized by communications founded on mutual trust, by shared perceptions of the importance of safety, and by confidence in the efficacy of preventive measures.32

Definitions of safety culture also include a focus on employee safety27 and several authors have started to develop theoretical models of patient safety culture.33-35 Overall though the theoretical development of patient safety culture as a construct in the existing peer-reviewed literature could be further developed and logic models underlying interventions to promote culture are often not reported.

### Safety Culture Versus Safety Climate?

Patient safety climate is a related term often used interchangeably with culture. Patient safety climate refers specifically to provider perceptions of patient safety-related norms, policies, and procedures that are shared among members of a group (care team, profession, unit, service, department, organization, system). The difference between culture and climate is often reduced to a difference in methodology, with studies involving surveys being categorized as measures of climate and ethnographic studies that involve detailed, longitudinal observations being categorized as studies of culture.

Practically, the differentiation between culture and climate is often viewed as a primarily academic exercise. However, the dichotomy raises an important and very practical point. If you are measuring safety culture using a survey, than you are measuring clinician and staff perceptions of culture (i.e., safety climate) and therefore in order to change culture you have to change perceptions of the relative priority of patient safety compared with other unit or organizational goals, and it must be salient to providers that their actions and attitudes supporting patient safety are actively reinforced by their peers and leaders. For example, it must be explicit that patient safety comes first relative to other unit or organizational goals, such as efficiency, and there must be visible recognition and positive outcomes related to engaging in safe behaviors.

For the purposes of this review we included studies of both patient safety culture and patient safety climate. In our discussion, we use the term patient safety culture to simplify the reporting of results.

### Measuring Patient Safety Culture

Patient safety culture has primarily been measured by patient safety climate surveys that capture employee perceptions of social, technical, and environmental aspects of their workplace. While the reviews of other patient safety practices focus on patient outcomes as the primary dependent variable and culture as a contextual variable, the present review focuses on changes in employee perceptions of patient safety culture as the primary dependent variable. We also include concurrently reported patient outcomes.

At least five previous reviews have been dedicated to survey instruments used to measure and assess patient safety culture.36-40 Their results indicate that the degree of psychometric evidence for reliability and validity varies significantly among the surveys designed to measure patient safety culture that have been published in the peer reviewed literature. Some of the surveys with the greatest amount of psychometric evidence in the published literature to date include the Hospital Survey on Patient Safety Culture,31 the Safety Attitudes Questionnaire,41 and the Patient Safety Climate in Healthcare Organizations survey.42 To ensure a foundational level of psychometrically sound measurement, the inclusion criteria for this review required that studies use a measure with evidence of reliability and validity available in the peer reviewed literature.

## What Are the Beneficial Effects of the Patient Safety Practice?

The systematic review of the literature resulted in 2696 unique articles that were potentially relevant to this topic. We excluded 2563 of these articles during abstract screening, leaving 133 for full article review. Of these 133 articles, we excluded 115, leaving 18 articles that addressed the benefits of interventions to improve patient safety culture.

Our systematic review identified 18 primary studies dedicated to evaluating safety-oriented interventions that were designed to promote a culture of patient safety, were conducted in an in-patient hospital, and measured patient safety culture/climate using a validated survey instrument. We did not identify any prior systematic reviews specifically dedicated to interventions designed to promote a culture of safety in health care.

Of the 18 studies reviewed, 12 were pre-post studies, 2 were cluster randomized control trials, 2 were concurrent control studies, 1 was a pre-post with concurrent control, and 1 was a quasi stepped-wedge design. Eleven studies measured patient safety culture/climate using the Safety Attitudes Questionnaire (SAQ),41 4 studies used the AHRQ Hospital Survey on Patient Safety (HSOPS),31 2 studies used the Patient Safety Climate in Healthcare Organizations survey (PSCHO),42 and 1 study utilized the Safety Climate Scale (SCS).43 Though the primary method of measuring patient safety culture/climate uses individual-level survey responses, culture is considered a group-level phenomenon. Thus, the majority of studies operationalized culture at the unit level of analysis. Three studies, however, operationalized culture at the hospital level of analysis.15,24,44 Sample sizes returned ranged from 5461 individual responses nested within 144 units within a single hospital system to 28 individuals nested within a single unit. Response rates ranged from 35% to 100% (see Summary Table and Evidence Tables).

The majority of interventions were multi-component interventions that combined several improvement strategies under a single overarching initiative to promote a culture of safety. For example, Belgen et al. 2010^19^ utilized a three component approach that included team-training, unit-based safety teams, and strategies for engaging patients in daily goal setting. Overall, 6 studies explicitly included teamwork and communication training and tools (e.g., structured briefings or debriefings), 4 explicitly included some form of executive walk rounds, and 4 explicitly used a multi-component approach known as the Comprehensive Unit Based Safety (CUSP) program (see Summary Table and Evidence Tables).

In terms of effectiveness, 9 of 18 (50%) reviewed studies reported a statistically significant impact of the intervention on the overall culture score, the safety climate score, or on at least half of reported survey items if analyzed at the item level. Several studies reported significant improvements in teamwork climate, but did not find similar improvements in safety climate (see Summary Table and Evidence Tables).20 None of the studies examining multi-component or bundled interventions examined the relative effectiveness of individual intervention components. Only one study directly compared the effectiveness of different interventions by comparing a simulation-based team training intervention to didactic-only team-training intervention18. Results indicated no change in safety culture survey scores for the didactic-only and control groups. An increase in teamwork climate was reported for the simulation-training group; however, this finding did not remain statistically significant after Bonferroni adjustment.

Seven studies also reported the impact of interventions on other outcomes, along with patient safety culture. In terms of patient outcomes, one study that found significant improvements in teamwork climate20 also found a significant decrease (0.56 vs. 0.15, p < .01) in the rate of reported errors that resulted in patient harm after implementation of a multi-faceted suite of interventions that included both cultural (e.g., feedback on errors in the form of posters and emails, education and training) and system-focused changes (e.g., CPOE, medication management protocols, changes to safety reports) implemented over 2.5 years. Another study found that the number of rapid response system activations that led to code events decreased from 29% to 22% following an intervention to promote safety culture in which paraprofessional care providers learned how to utilize structured communication methods to communicate changes in patient status. However, this difference was not tested statistically. Another study that reported a marginal increase in teamwork climate18 also found that the experimental unit's weighted adverse outcome score decreased by 37% after implementation of a team training program designed to promote patient safety culture, compared with a 43% increase in a control unit (p < .05). One study also provided descriptive information on reductions in nurse turnover from 27% to 0% for two years following implementation of the CUSP program, but no statistical analysis was reported (see Summary Table and Evidence Tables).26

The evidence to date suggests that several practices may help to promote a culture of safety; however, methodologic issues related to variation in the practices studied and outcomes reported, extremely small sample sizes, and lack of cluster randomized trials constrain the evidence for intervention effectiveness available to date. Robust evaluations are needed that assess the impact of practices to promote patient safety culture across multiple outcomes, based on theoretically sound evaluation models. One previous review of interventions to promote safety culture also noted methodological constraints in primary studies45 and one previous review dedicated to strategies to improve culture concluded that there was [underlined: no] rigorous evidence available in the current literature to demonstrate their effectiveness.46 While the criteria for the previous work finding no studies that met inclusion criteria46 were more stringent than those utilized in the present review, this conclusion supports our finding that the robustness with which interventions to promote culture are studied, evaluated, and reported is in need of improvement.

In terms of grading, the strength of evidence for this topic was low. Risk of bias was generally high due to study design issues - we identified only one true cluster RCT17 Major issues affecting risk of bias for many studies included low response rates for surveys and incomplete reporting (not reporting all units or hospitals where interventions were conducted, and not reporting results for all parts of the culture survey but focusing only on those that were statistically significant). Results were inconsistent: findings in half of the studies were not statistically significant and significant findings were difficult to compare due to variations in measurement methods. With respect to directness, the intervention was often not specifically designed to improve patient safety culture, and actual patient safety outcomes were infrequently reported. Finally, with respect to precision, a number of different survey instruments were used and were often reported differently in the articles, so no conclusions could be drawn (see Evidence Table on Risk of Bias).

## What Are the Harms of the Patient Safety Practice?

None of the studies included in this review explicitly evaluated harms of culture interventions or surveys.

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

The effectiveness of the various methods for promoting a culture of safety likely varies based upon the characteristics of the intervention and implementation processes. The interventions reported in the 18 studies we reviewed differed in terms of the characteristics of the organizations in which they were implemented, the level of leadership support and engagement reported, and in the tools and strategies utilized to support implementation and to transfer the intervention to daily care processes. Ten studies were conducted exclusively in academic hospital settings, 3 studies were conducted in community based hospital settings, 4 studies explicitly included a mix of academic and community hospitals, and several studies did not explicitly address the hospital mix included in their sample. One study also reported that the gain in safety culture scores was larger for faith-based hospitals; however statistical analyses of these reported differences were not reported.23

This review also highlights the largely atheoretical nature of the research to date regarding the development and implementation of interventions to promote patient safety culture. Only 3 of the 18 reviewed studies (17%) noted any form of theoretical grounding for their improvement and implementation strategy. Conceptual theories of patient safety culture and culture change are foundational features of a clear logic model that guides intervention design and implementation. Future studies should dedicate greater effort to developing and reporting the underlying theoretical model driving intervention design and improvement efforts. Such models are a critical element to furthering our understanding of the role context plays in moderating the effects of various interventions to promote safety culture (Table 1).

Table 1, Chapter 33 Results of included studies on patient safety culture

Author, Year | Description of PSP | Study Design | Outcomes: Benefits^*^
Abstoss, 2011^20^ | 4 culture & 3 system-level interventions | Pre-post | Culture survey: N Teamwork: Y Reported errors resulting in harm: Y Overall reporting rate:
Adams-Pizarro,2011^24^ | Multi-component intervention | Pre-post | Culture survey: No statistical tests reported
Blegen, 2010^19^ | Multi-component intervention | Pre-post | Culture survey: Y
Cooper, 2008^44^ | Crisis resource management training | pre-post with control hospitals | Culture survey: N
Donahue, 2011^16^ | Paraprofessionals communication training | Pre-post | Culture survey: No statistical tests reported Use of structured communication: No statistical tests reported Rapid response events that led to code events: No statistical tests reported
Edwards, 2008 47 | Multi-component intervention | Pre-post | Culture survey: Y
Frankel, 2008^15^ | Executive walkrounds | Pre-post | Culture survey: Y
O'Leary, 2010^13^ | Structured Inter-Disciplinary Rounds | Concurrent control | Culture survey: N Teamwork: Y
O'Leary, 2011^12^ | Structured Inter-Disciplinary Rounds | Concurrent control | Culture survey: Y Teamwork: Y
Paine, 2010^25^ | Multiple interventions | Pre-post | Culture survey: Y
Pettker, 2009^22^ Pettker, 2011^21^ | Multi-component | Pre-post | Culture survey: Y Adverse outcomes: Y
Pronovost, 2005 48 | Comprehensive Unit-Based Safety Program | Quasi stepped-wedge design | Culture survey: Y Nurse turnover: N Length of stay: Y
Riley, 2011^18^ | TeamSTEPPS training | Cluster RCT | Culture survey: N Adverse outcomes: Y
Sexton, 2011^23^ | Comprehensive Unit-Based Safety Program | Pre-post | Culture survey: Y
Thomas, 2005^17^ | Executive walkrounds | Cluster RCT | Culture survey: N overall; Y when analyzed by exposure to intervention
Tiessen, 2008^14^ | Multi-component intervention | Pre-post | Culture survey: N
Timmel, 2010^26^ | Comprehensive Unit-Based Safety Program | Pre-post | Culture survey: Y Nursing turnover: No statistical tests reported

* Overall results statistically significant – Yes or no

## Are There Any Data About Costs?

None of the reviewed studies directly evaluated the cost-effectiveness of practices designed to promote a culture of safety. However, one study attempted to examine how a multifaceted intervention that included interdisciplinary rounding and regular interdisciplinary meetings affected adjusted per-patient care costs. Compared with a control unit, adjusted costs of care were reported as $24 less for intervention unit patients; however, the study was underpowered, and this was not a statistically significant difference.13

## Are There Any Data About the Effect of Context on Effectiveness?

None of the reviewed studies directly evaluated the effect of context on intervention effectiveness; however, there is a clear need to determine the impact of contextual features in promoting a culture of safety.

## Conclusions and Comment

We found low strength of evidence that interventions to improve safety culture can improve culture as an outcome, and insufficient evidence that interventions to improve culture can improve patient safety outcomes, due to very few studies measuring these outcomes, and the heterogeneity across interventions and types of safety outcomes reported. Although there is an emerging evidence base dedicated to examining practices that promote a culture of safety, future work must make large gains in robustness of experimental design and methodologies for measuring culture in order to meaningfully advance our understanding of how to promote safety culture effectively.

The evidence to date suggests that practices to promote patient safety culture may be beneficial; however, evaluation designs and the rigor of available evidence do not support strong causal conclusions. For example, the studies reviewed did not evaluate the mechanisms through which these interventions impact culture. Additionally, most of the interventions reviewed had multiple components, but none of the studies examined the incremental impact of each component of the intervention. Future studies should strive to clearly evaluate the incremental and differential impact of individual components of multifaceted intervention strategies.

Future research efforts should also aim to further our understanding of how providers formulate their perceptions of safety culture. While there is a significant literature on the etiology of safety culture (i.e., how individuals and groups formulate their perceptions of culture) in the organizational sciences, little work has been done in health care to understand how providers formulate their individual perceptions of safety culture and how these perceptions become shared with others in their unit, department, or care team. Understanding how perceptions of patient safety culture form and come to be shared among health care workers is a critical component of understanding how to effectively promote and improve safety culture. There is a rich theoretical and empirical literature from the organizational sciences that can be drawn upon to enhance the strength of studies examining interventions to promote a culture of safety within health care.

Most important, this review underscores that the interventions designed to promote culture need to be more rigorously tested and reported. Few studies to date have applied rigorous evaluation designs or have clearly articulated critical aspects of study execution in peer reviewed outlets. Findings from our review mirror those of other reviews45,46,49 that examined the effectiveness of strategies to change organizational culture to improve health care performance. Collectively results suggest some homogenous evidence for interventional strategies such as team-training, executive engagement strategies, and unit-based improvement processes. They also highlight the need for more rigorous evaluations of patient safety practices designed to promote safety culture. A summary table is following (Table 2).

Table 2, Chapter 33 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Low-to-high | Low | Uncertain | Low-to-moderate (varies) | Moderate/Not difficult-to-Moderate (varies with intervention)

## References

1 Braithwaite J, Westbrook MT, Travaglia JF, Hughes C. Cultural and associated enablers of, and barriers to, adverse incident reporting. Qual Saf Health Care. 2010;19(3):229-33. [pmid: 20534716].
2 Singer SJ, Gaba DM, Geppert JJ, Sinaiko AD, Howard SK, Park KC. The culture of safety: results of an organization-wide survey in 15 California hospitals. Qual Saf Health Care. 2003;12(2):112-8. [pmid: 12679507].
3 Moody RF, Pesut DJ, Harrington CF. Creating safety culture on nursing units: Human performance and organizational system factors that make a difference. J Patient Saf. 2006;2(4):198-206.
4 Zohar D, Luria G. A multilevel model of safety climate: cross-level relationships between organization and group-level climates. J Appl Psychol. 2005;90(4):616-28. [pmid: 16060782].
5 Weingart SN, Farberstein K, Davis RB, Phillips RS. Using a multihospital survey to examine the safety culture. Joint Commission Journal on Quality and Patient Safety. 2004;30(3):125-132.
6 Naveh E, Katz-Navon T, Stern Z. Treatment errors in healthcare: A safety climate approach. Management Science. 2005;51(6):948-960.
7 Estabrooks CA, Tourangeau AE, Humphrey CK, et al. Measuring the hospital practice environment: a Canadian context. Res Nurs Health. 2002;25(4):256-68. [pmid: 12124720].
8 Sexton JB. 2002. A matter of life or death: Social, psychological, and organizational factors related to patient outcomes in the intensive care unit. Dissertation. University of Texas, Austin.
9 Mardon RE, Khanna K, Sorra J, Dyer N, Famolaro T. Exploring relationships between hospital patient safety culture and adverse events. J Patient Saf. 2010;6(4):226-32. [pmid: 21099551].
10 Singer S, Lin S, Falwell A, Gaba D, Baker L. Relationship of safety climate and safety performance in hospitals. Health Serv Res. 2009;44(2 Pt 1):399-421. [pmid: 19178583].
11 Weaver SJ. 2011. A configural approach to patient safety climate: The relationship between climate profile characteristics and patient outcomes. Dissertation. University of Central Florida, Orlando.
12 O'Leary KJ, Haviley C, Slade ME, Shah HM, Lee J, Williams MV. Improving teamwork: impact of structured interdisciplinary rounds on a hospitalist unit. J Hosp Med. 2011;6(2):88-93. [pmid: 20629015].
13 O'Leary KJ, Wayne DB, Haviley C, Slade ME, Lee J, Williams MV. Improving teamwork: impact of structured interdisciplinary rounds on a medical teaching unit. J Gen Intern Med. 2010;25(8):826-32. [pmid: 20386996].
14 Tiessen B. On the journey to a culture of patient safety. Healthc Q. 2008;11(4):58-63. [pmid: 18818531].
15 Frankel A, Grillo SP, Pittman M, et al. Revealing and resolving patient safety defects: the impact of leadership WalkRounds on frontline caregiver assessments of patient safety. Health Serv Res. 2008;43(6):2050-66. [pmid: 18671751].
16 Donahue M, Miller M, Smith L, Dykes P, Fitzpatrick JJ. A leadership initiative to improve communication and enhance safety. Am J Med Qual. 2011;26(3):206-11. [pmid: 21224466].
17 Thomas EJ, Sexton JB, Neilands TB, Frankel A, Helmreich RL. The effect of executive walk rounds on nurse safety climate attitudes: a randomized trial of clinical units[ISRCTN85147255]. BMC Health Serv Res. 2005;5(1):28. [pmid: 15823204].
18 Riley W, Davis S, Miller K, Hansen H, Sainfort F, Sweet R. Didactic and simulation nontechnical skills team training to improve perinatal patient outcomes in a community hospital. Jt Comm J Qual Patient Saf. 2011;37(8):357-64. [pmid: 21874971].
19 Blegen MA, Sehgal NL, Alldredge BK, Gearhart S, Auerbach AA, Wachter RM. Improving safety culture on adult medical units through multidisciplinary teamwork and communication interventions: the TOPS Project. Qual Saf Health Care. 2010;19(4):346-50. [pmid: 20693223].
20 Abstoss KM, Shaw BE, Owens TA, Juno JL, Commiskey EL, Niedner MF. Increasing medication error reporting rates while reducing harm through simultaneous cultural and system-level interventions in an intensive care unit. BMJ Qual Saf. 2011.
21 Pettker CM, Thung SF, Raab CA, et al. A comprehensive obstetrics patient safety program improves safety climate and culture. Am J Obstet Gynecol. 2011;204(3):216.e1-6. [pmid: 21376160].
22 Pettker CM, Thung SF, Norwitz ER, et al. Impact of a comprehensive patient safety strategy on obstetric adverse events. Am J Obstet Gynecol. 2009;200(5):492.e1-8. [pmid: 19249729].
23 Sexton JB, Berenholtz SM, Goeschel CA, et al. Assessing and improving safety climate in a large cohort of intensive care units. Crit Care Med. 2011;39(5):934-9. [pmid: 21297460].
24 Adams-Pizarro I, Walker ZA, Robinson J, Kelly S, Toth M. Using the AHRQ Hospital Survey on Patient Safety Culture as an Intervention Tool for Regional Clinical Improvement Collaboratives. 2008.
25 Paine LA, Rosenstein BJ, Sexton JB, Kent P, Holzmueller CG, Pronovost PJ. Assessing and improving safety culture throughout an academic medical centre: a prospective cohort study. Qual Saf Health Care. 2010;19(6):547-54. [pmid: 21127113].
26 Timmel J, Kent PS, Holzmueller CG, Paine L, Schulick RD, Pronovost PJ. Impact of the Comprehensive Unit-based Safety Program (CUSP) on safety culture in a surgical inpatient unit. Jt Comm J Qual Patient Saf. 2010;36(6):252-60. [pmid: 20564886].
27 Zohar D. Thirty years of safety climate research: Reflections and future directions. Accident Analysis and Prevention. 2010;42(5):1517-1522. [pmid: 20538108].
28 Schein EH. Organizational leadership and culture. 4th edition. San Francisco. Jossey-Bass. 2010.
29 Hartmann CW, Meterko M, Rosen AK, et al. Relationship of hospital organizational culture to patient safety climate in the Veterans Health Administration. Med Care Res Rev. 2009;66(3):320-38. [pmid: 19244094].
30 Singer SJ, Falwell A, Gaba DM, et al. Identifying organizational cultures that promote patient safety. Health Care Manage Rev. 2009;34(4):300-11. [pmid: 19858915].
31 Sorra JS, Nieva VF. Hospital Survey on Patient Safety Culture. AHRQ Publication No. 04-0041. September. 2004. Agency for Healthcare Research and Quality. Rockville, MD. www.ahrq.gov/qual/patientsafetyculture/usergd.htm.
32 Organising for Safety: Third Report of the ACSNI (Advisory Committee on the Safety of Nuclear Installations) Study Group on Human Factors. Health and Safety Commission (of Great Britain). Sudbury, England. HSE Books. 1993.
33 Reiman T, Pietikainen E, Oedewald P. Multilayered approach to patient safety culture. Qual Saf Health Care. 2010;19(5):e20. [pmid: 20724396].
34 Kirk S, Parker D, Claridge T, Esmail A, Marshall M. Patient safety culture in primary care: developing a theoretical framework for practical use. Qual Saf Health Care. 2007;16(4):313-20. [pmid: 17693682].
35 Parker D, Lawrie M, Carthey J, Coultous M. Framework for Understanding the Development of Organizational Safety Culture. Clinical Risk. 2008;14(4):140-142.
36 Colla JB, Bracken AC, Kinney LM, Weeks WB. Measuring patient safety climate: a review of surveys. Qual Saf Health Care. 2005;14(5):364-6. [pmid: 16195571].
37 Flin R, Burns C, Mearns K, Yule S, Robertson EM. Measuring safety climate in health care. Qual Saf Health Care. 2006;15(2):109-15. [pmid: 16585110].
38 Flin R. Measuring safety culture in healthcare: A case for accurate diagnosis. Safety Science. 2007;45:653-667.
39 Jackson J, Sarac C, Flin R. Hospital safety climate surveys: measurement issues. Curr Opin Crit Care. 2010.
40 Singla AK, Kitch BT, Weissman JS, Campbell EG. Assessing patient safety culture: A review and synthesis of the measurement tools. J Patient Saf. 2006;2:105-115.
41 Sexton JB, Helmreich RL, Neilands TB, et al. The Safety Attitudes Questionnaire: psychometric properties, benchmarking data, and emerging research. BMC Health Serv Res. 2006;6:44. [pmid: 16584553].
42 Singer S, Meterko M, Baker L, Gaba D, Falwell A, Rosen A. Workforce perceptions of hospital safety culture: development and validation of the patient safety climate in healthcare organizations survey. Health Serv Res. 2007;42(5):1999-2021. [pmid: 17850530].
43 Sexton JB, Helmreich RL, Williams R, et al. The Flight Management Attitudes Safety Survey (FMASS). Research Project Technical Report 01-01. Austin, TX. The University of Texas. 2001.
44 Cooper JB, Blum RH, Carroll JS, et al. Differences in safety climate among hospital anesthesia departments and the effect of a realistic simulation-based training program. Anesth Analg. 2008;106(2):574-84. table of contents. [pmid: 18227319].
45 Morello RT, Lowthian JA, Barker AL, McGinnes R, Dunt D, Brand C. Strategies for improving patient safety culture in hospitals: a systematic review. BMJ Qual Saf. Jul. 31. [Epub ahead of print].
46 Parmelli E, Flodgren G, Beyer F, Baillie N, Schaafsma ME, Eccles MP. The effectiveness of strategies to change organisational culture to improve healthcare performance: a systematic review. Implement Sci. 2011;6:33. Notes: GENERAL NOTE: NLM: Original Date Completed: 20110714.
47 Edwards P, Scott T, Richardson P, et al. Using staff perceptions on patient safety as a tool for improving safety culture in a pediatric hospital system. Journal of Patient Safety. 2008;4(2):113-8.
48 Pronovost P, Weast B, Rosenstein B, et al. Implementing and validating a comprehensive unit-based safety program. Journal of Patient Safety. 2005;1(1):33-40.
49 Kapinos KA, Fitzgerald P, Greer N, Rutks I, Wilt TJ. The Effect of Working Conditions on Patient Care: A Systematic Review. VA-ESP Project #09-009. 2012.