# Promoting Engagement by Patients and Families To Reduce Adverse Events (NEW)

## How Important Is the Problem?

Patient-centeredness is now widely recognized as a central aspect of health care, including hospital care. Each patient has unique needs that should be addressed by each hospital in order to improve safety and quality.1 Through patient engagement in their own safety, they and their families can help prevent adverse events.2-5 Such involvement is promoted by several international organizations, and educational materials have been developed to facilitate patient engagement in safety practices.6 In order to evaluate how patient engagement is being implemented and the effectiveness of this safety practice, we performed a systematic review of Medline, CINAHL, Embase, and Cochrane from 2000-2011, with a variety of synonyms for patient engagement and patient safety, including physician-patient relations, patient participation, and patient-centered care.

## What Is the Patient Safety Practice?

Compared with other patient safety practices, promoting patient and family engagement does not lend itself to a precise definition as easily. Engagement can be seen as an “umbrella term” incorporating various approaches rather than a specific process, team, or technology. In general, definitions seem to center on patient and family participation in care, whether from the point of view of humanism, consumer rights, or care coordination, being used to encourage the patient to be active in reporting adverse events.7,8

For that reason, patient and family engagement can be understood as a patient safety practice in various ways, not all of which are included in this chapter. First, patient engagement can be approached as an overarching philosophy applicable to a number of patient safety practices including reducing patient risk of suicide (Chapter 26) and improving care transitions at discharge (Chapter 37).

Secondly, patient engagement can be understood as an implementation in its own right. Few patient safety interventions are implemented with the sole primary goal of promoting patient and family engagement. For example, it is relatively common for another PSP, such as Rapid Response Systems or Rapid Response Teams (RRT), to be implemented with the primary goals of improving care quality and safety. Promotion of patient engagement may be a secondary goal, and data regarding the change in patient engagement after implementation of the RRT intervention may not be reported. Also, in some patient safety interventions, patient engagement may be treated as a contextual variable that may moderate the efficacy of the intervention.

Although engagement can be challenging to define, this review focused on the effectiveness of interventions intended primarily to elicit patient or family involvement in reducing the incidence of adverse patient safety events. In addition, patient/family engagement was examined as part of the implementation of selected patient safety practices with other primary goals (eg. RRT interventions).

## Why Should This Patient Safety Practice Work?

Schwappach2 provided a conceptual framework for patient engagement based on the Theory of Planned Behavior, which emphasizes the importance of beliefs and attitudes in creating intentions and changing actual behavior. Since patients are the only members of the treatment team who are always (theoretically) present at every treatment and visit, they provide important information that may not be available from other sources, such as medical records. In addition, many patients prefer to be involved in their care in general, which may also apply to the safety and quality of care.2 Relating to this, patients have also been found to be highly motivated to decrease the risk of harm and ensure good outcomes.9 Finally, since many safety problems occur at the bedside and can be observed and potentially prevented by patients, they are both an important source of information on potential problems and a potential mechanism for improving safety.7

## What Are the Beneficial Effects of the Patient Safety Practice?

The systematic review of the literature resulted in 4,107 unique articles that were potentially relevant to this topic. English-language studies from the U.S., UK, Canada, and Australia were included in the present review, due to potentially significantly different cultural issues in patient engagement in their health care outside of these countries, as well as potential differences in tools for promoting engagement. We included studies that focused on hospital care settings only (e.g., intensive care units), because we felt that patient engagement in safety in the home setting would be difficult to differentiate from patient self-management of their medications and care, when providers are not present. Finally, only systematic reviews focusing on effectiveness and prospective, controlled studies were included.

A total of 4,061 of these articles were excluded during abstract screening, leaving 46 for full article review. Of these 46 articles, 43 were excluded, leaving three articles that met inclusion criteria for studies evaluating the effectiveness of interventions focusing on patient engagement in patient safety in the hospital setting, focusing on the patient safety practices that are addressed in other chapters in this report. We identified one systematic review of patient and family engagement in safety.10 The authors found limited evidence, of poor quality, for the benefit of patient involvement in patient safety, and found that the available studies were mostly concerned with patient management of medications.7,11,12We identified three studies that evaluated the impact of interventions for patient/family engagement in patient safety in the hospital setting (Table 1).

Table 1, Chapter 32 Patient engagement in safety: effectiveness studies

Author, Year | Description of PSP Multiple Interventions or Multifaceted Interventions | Study Design Sample Size | Outcomes: Benefits^*^
Weingart 2004 13 | Proving patients with personalized medication list to help prevent medication errors | RCT 209 | Adverse drug event rate: N Close-call rate: N
McGuckin 2004 14 | Asking all health care workers who had direct contact with them, “Did you wash/sanitize your hands? | Pre-post 35 | Hand hygiene per resident day: Y
Stone 2007 15 | Instructing patients to ask health care workers to clean their hands. | Pre-post 187 | Total alcohol hand rub and soap-use per patient day: Y

* Statistical significance, Y (Yes) or N (No)

One study13 was a randomized controlled trial (N=209) of an intervention to provide patients with a personalized medication list. Both intervention and control groups were provided with general education about drug safety. Measurements to determine incidence of adverse drug events and close-calls included patient surveys and identification of incidents through interviews of pharmacists, interviews of housestaff, and electronic medical record review. The study was conducted in a teaching hospital without computerized physician order entry. This study found no statistically significant benefits of the intervention compared with the control group: in 1,053 total patient-days at risk, the adverse drug event rate was 8.4 percent in the intervention group and 2.9 percent in the control group (p=0.12). The close-call rate also showed no significant change, 7.5 percent versus 9.8 percent (p=0.57).

McGuckin and colleagues14 conducted a pre-post study for hand hygiene among 35 patients located on an inpatient rehabilitation unit in an acute-care hospital. Using a patient education model, a 6-week study with a 3-month followup was conducted. During the intervention, patients agreed (and were encouraged) to ask all health care workers with direct contact if they had washed/sanitized their hands. Use of soap and sanitizer per resident-day was measured before, during, and after the intervention. While the intervention itself was not multifaceted, multiple methods were used to encourage patients to ask the handwashing question of their providers: a visit by a premedical student with the patient to discuss hand hygiene (HH); an education brochure; and multiple prompts for patients to ask their providers, including videos and visual aids. Hand washing or sanitizing increased from five HH uses per resident-day during the intervention to 9.7 HH per resident-day during the intervention (p<0.001), 6.7 HH per resident-day post-intervention (at 6 weeks) (p<0.001) and 7.0 HH per resident day at 3 months (p<0.001). Patients asked their physicians about hand hygiene 40 percent of the time, and their nurses 95 percent of the time.

Stone and colleagues15 carried out a pre-post study among 187 acute-care hospitals in the National Health System of the United Kingdom that included patient engagement as part of a multifaceted HH intervention. A HH campaign was introduced to these hospitals over a period of 7 months, including alcohol hand rub near the patients' bedside, regularly changed wall posters in the wards regarding HH, and materials telling patients to ask their providers to clean their hands. Median use of alcohol hand rub increased statistically significantly in the participating hospitals during the intervention period, from seven to 13 ml per bed-day of alcohol hand rub over 6 months (p<0.001); the change in soap use was not statistically significant (p=0.06). Rate of hospital-acquired infections did not change.

Because of the small number of studies meeting our criteria, and their heterogeneity, we could not perform evidence grading.

## What Are the Harms of the Patient Safety Practice?

None of the studies included in this review evaluated harms of interventions or surveys. Interventions to increase patient engagement, such as reminding health care workers to wash their hands, could theoretically adversely affect provider-patient relationships and patients' trust in their providers. Patients might fear adverse consequences, or health care providers could become overly reliant on patient engagement and more lax in their own safety practices.6

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

Patient engagement is part of several key organizations' approach to patient safety. The World Health Organization provides educational materials for patients, and The Joint Commission National Patient Safety Goals include the “Speak Up” campaign to engage patients in preventing wrong-site surgery. Bergal and colleagues assessed patients' reliability in regard to marking the site of planned surgery and found only partial compliance (68%). A review by McGuckin and colleagues16 assessed the importance of patient role (which they term patient empowerment) in HH interventions. Three of the cited studies (themselves authored by McGuckin and colleagues) showed that, while 80 to 90 percent of patients reported willingness to ask their health care workers to wash their hands, 60 to70 percent of patients actually did so. Because of the paucity of literature, the authors were unable to conduct a systematic review. Patient participation in safety practices may be influenced by societal norms and the health care environment, including whether the organizational culture supports patients' participation.7

Patient engagement interventions have been applied to a number of individual patient safety practices addressed elsewhere in this report. These practices include hand hygiene, rapid response teams, surgical site marking, and falls. Examples of implementation studies in patient engagement are described below.

### Patient Engagement in Implementation of Hand Hygiene Interventions

A review by McGuckin and colleagues17 addressed patient empowerment as an approach to motivating strategies in hand hygiene (HH) interventions (Table 2). As summarized in Chapter 8 (Hand Hygiene Compliance) above, the authors estimated from the literature the proportion of patients who stated their desire to be empowered, or engaged, in reminding health care workers to wash their hands. However, the proportion of patients who endorsed readiness for engagement (or empowerment) was not always congruent with the proportion of patients who asked their health care workers about HH. The authors identify several barriers discussed in the literature to patients' activating their engagement, emphasizing the negative social reaction that patients might feel when asking their HCWs about HH. Finally, McGuckin and colleagues emphasize that the literature on patient empowerment in HH is lacking estimates of effectiveness.

Table 2, Chapter 32 Hand-hygiene intervention studies

Author, Year | Main Study Objective | Implementation Themes
McGuckin, 2011 17 | Review of patient empowerment motivating strategies in hand hygiene intervention | Tools: educational tools, motivation and reminder tools, and role modeling Facilitators/barriers: Social barrier of patient to confront health care workers; Lack of evidence of effectiveness

### Patient Engagement in Implementation of Rapid Response Team Interventions

Three studies considered patient engagement in the context of Rapid Response Teams (RRT) (Table 3). Ray and colleagues18 implemented a pediatric RRT based on direct family activation, an approach developed to “empower family members to seek help when serious concerns arise.” The “direct family activation” itself was a direct telephone number to reach the RRT, which families could reach from any room in the hospital. In addition, families were educated via posters in patients' rooms and flyers. In-person “family awareness surveys” assessed families' awareness of the family activation approach. Nurses were trained in how to explain the RRT activation to families. They were also given reminders in the electronic medical record and given feedback on levels of family awareness from the surveys. After implementation of family activation, the number of RRT calls per 1,000 discharges increased from 16 to 24, though no statistical tests were employed to assess significance.

Table 3, Chapter 32 Rapid response team intervention studies

Author, Year | Main Study Objective | Implementation Themes
Ray, 2009^18^ | To implement a pediatric RRT based on direct family activation | Tools: direct telephone number to reach the RRT which families could reach from any room in the hospital, posters, flyers Staff/education: mock script to help medical team discuss RRT activation with patients/families Facilitators/barriers: physicians concerned that their role would be undermined; providers' understanding of RRT as extension of care they already provide
Dean, 2008^19^ | To integrate patients and families into an RRS at a children's hospital | Tools: telephone number to activate RRT available to patients/families 24 hours, 7 days a week Staff/education: explanation by admitting unit's nurse to patient and family, reinforced by video and brochure Facilitators/barriers: leadership, provider involvement
Gerdik, 2010^20^ | To implement a patient- and family-activated RRT at an acute care hospital | Tools: dedicated phone line Staff/education: patient and family education Facilitators/barriers: concern that resources would be overwhelmed; endorsement of hospital administration, physicians, and staff

Dean and colleagues19 described a similar early warning system that “empowers patients and families to serve as an additional line of patient-safety defense” by integrating them into the RRT system of a major children's hospital. This study specified the conditions under which patients or families were encouraged to call the RRT, including a noticeable medical change in a patient that had been unaddressed; a breakdown in care or uncertainty regarding treatment; the administration of a medication that causes an adverse effect or that the patient/family believed had not been sufficiently explained; or the provision of treatment that the patient or family believed was meant for another patient or contravened their doctors' wishes. Apart from the criteria under which the alert system was to be activated, this study did not detail how patients or families were to be empowered or educated to overcome any barriers to using the system. From September 2005 through August 2007, the early warning system responded to 42 calls from patients and parents; the authors state that the root cause for all calls was miscommunication between patient and provider.

Gerdik and colleagues20 studied the implementation of a family- and patient-activated rapid response team in an acute care hospital. Picker's “Eight Dimensions of Patient-Centered Care” provided the conceptual framework, including the “involvement of family of friends,” which includes “involving family in decision-making.” However, no explicit attention to patient or family engagement was otherwise given. Implementation of the family-/patient-activated RRT involved written educational materials, informational signs, instructional labels for telephones, and scripted education and training on the part of staff. After RRT activation, patient and family satisfaction were assessed. Following implementation of the RRT, codes decreased significantly outside the ICU, from 25/month to 17/month. Patients and families alike were found to be satisfied with the RRT.

These studies of family and patient engagement in RRT evaluated implementation and did not explicitly set out to evaluate effectiveness. However, in the study by Gerdik and colleagues20, after implementation of the RRT, codes outside the ICU decreased, potentially representing a measure of effectiveness.

### Patient Engagement in Implementation of Fall Interventions

Chapter 19 addresses patient safety practices to reduce the incidence of in-facility falls. While multi-modal interventions were found throughout the literature, including those incorporating patient education, none of the studies reviewed specifically address patient engagement.

Two studies were identified in the search for this review (Table 4). Krauss and colleagues21 implemented an educational intervention to reduce patient falls according to a quasi-experimental design among nursing staff, nursing secretaries, and patient care technicians in an academic hospital. While patient or family activation or engagement were not mentioned specifically as part of the implementation or its conceptual background, nurses were directed to educate all patients in fall prevention. For patients with high risks of falling, nursing staff were instructed to reinforce falls-prevention education with both patients and family. Staff received feedback on fall rates on their unit during the implementation via meetings and flyers. The nursing staff's knowledge and use of prevention strategies improved. The incidence of in-hospital falls decreased for 5 months but the decrease for the full 9-month intervention period was not significant.

Table 4, Chapter 32 Falls prevention intervention studies

Author, Year | Main Study Objective | Implementation Themes
Krauss, 2008^21^ | To implement an educational intervention among nursing staff, nursing secretaries, and patient care technicians to reduce falls in an academic hospital | Tools: educating all patients and families in fall prevention, patient pamphlets Staff/education: Nurses, patient care technicians, and unit secretaries all took part in education modules Facilitators/barriers: staff turnover; high patient-to-nurse ratios; high patient turnover or high patient volume; competing demands on nursing staff; lack of buy-in from staff
van Gaal, 2011^22^ | To implement a multi-component intervention, including patient involvement, to reduce the risk of pressure ulcers, falls, and urinary tract infections in ten wards from four hospitals and ten wards from six nursing homes | Tools: education, patient involvement and feedback on process and outcome Staff/education: Key nurses on each unit implemented small-scale educational program, two case discussions on every ward, and distributed a CD-ROM with educational material Facilitators/barriers: complexity of intervention

van Gaal and colleagues22 implemented a multi-component intervention to reduce the risk of pressure ulcers, falls, and urinary tract infections in ten wards from four hospitals and ten wards from six nursing homes. Patient involvement was conceived as part of the intervention and was included because it can “enhance the implementation of innovations or improvements.” Oral and written information was given to patients at risk for specific adverse advents. Implementation on every participating ward included educational meetings for nurses and informational brochures for patients at risk for any one of the adverse events addressed. Fewer falls per patient week were found the participating hospital wards and nursing homes, but the study was not powered to determine the statistical significance of the decreased incidence of particular adverse events.

### Patient Engagement in Implementation of Surgical Checklist Interventions

Most studies of inventions to prevent wrong-site surgery have focused on checklists for surgeons or anesthesiologists to perform prior to surgery.23-25 Although patient interaction may be part of the checklist, such as verbally verifying patient identity and surgical site,23 the provider team is the target of the intervention. Only two studies have examined patient engagement as a means to avoid wrong-site surgery (Table 5). One study, in the setting of a private foot-and-ankle practice, gave patients written instructions to mark the limb not to be operated on with the label “NO” and observed patient compliance of 59 percent on the day of surgery.26 The other study, in the setting of a university-affiliated orthopedic practice, gave patients both verbal and written instructions to mark the intended surgical site with the label “YES” and provided a marking pen to do so.27 Patient compliance in this study was 68.2 percent, with higher compliance in patients whose primary language was English and whose surgery occurred sooner after instructions were given.

Table 5, Chapter 32 Surgical checklist intervention studies

Author, Year | Main Study Objective | Implementation Themes
Bergal, 2010^27^ | To investigate patient compliance in marking surgical site | Tools: verbal and written instructions to mark surgical site, marking pen provided; assessment for compliance on day of surgery Barriers/facilitators: patients' primary language, cultural tendency to rely on physicians, younger patient age, time between enrollment and surgery
DiGiovanni, 2003^26^ | To investigate patient compliance in marking surgical site | Tools: written instructions to mark limb NOT to be operated on; assessment for compliance on day of surgery

### Patient Engagement in Implementation of Care Transition Interventions

Patient engagement is defined in a variety of ways. Depending on the definition, the practical implications can be broader or more specific. While in the rest of this chapter we address interventions centered on patient engagement as an independent element and on interventions where patients assume a primary role in patient safety, an additional important and valuable route to patient engagement is to encourage patient activation in an existing intervention, as one part of a larger approach. Patient engagement in transitional care is an important example of this broader approach.

Interventions to improve transitional care at the time of hospital discharge are examined in Chapter 37. Patient engagement is one of many aspects of these patient safety practices. Pre-discharge interventions may include patient engagement in the form of patient and/or caregiver education. Post-discharge interventions may include outreach to patients and/or caregivers by means of follow-up phone calls or other methods. “Bridging” interventions may include a combination of these and other components.

Only one intervention, the Care Transitions Intervention (CTI), had been implemented and evaluated in multiple settings.28-32 The CTI is designed to provide patients and caregivers with the tools and skills to take a more active role in their care. It is based on four pillars of medication self-management: a patient-centered record, follow-up, and identification of “red flags” with instructions on how to respond to them. Patients and care-givers received in-hospital visits, telephone calls, home visits, encouragement to take an active role in care, and guidance from a “transition coach.” Efficacy studies of CTI have shown reduced rates of readmission in clinical trials set in a not-for-profit capitated delivery system28,29and a Medicare fee-for-service system.33 Assessment of patient engagement as the mediator of reduced readmission have shown that patients receiving CTI reported high levels of confidence in self-management, understanding warning symptoms of worsening condition, ability to obtain needed information during follow-up visits, and understanding of how to take their medications.29

Implementation studies of CTI in “real-world” settings have also shown reduced readmissions for patients who received coaching compared with those who did not. Implementation issues included the training and time commitment of transition coaches and the challenge of recruiting and retaining patients in the intervention.31 Studies that directly addressed sustainability emphasized the importance of leadership, hospital-community partnerships, tailoring to the needs of diverse communities and particular patient subgroups, and resource allocation (staff and funding) as important factors in implementation. Mean patient activation scores were moderately higher for sites with full sustainability plans than for sites with partial or minor plans, suggesting that greater engagement in the program at the site level could affect engagement by patients receiving the intervention.32 Qualitative data indicate that patient perceptions of a caring relationship with transition coaches foster greater patient engagement in the program, with implications for staff training.33

## Are There Any Data About Costs?

None of the reviewed studies directly evaluated the costs or cost-effectiveness of practices designed to promote patient or family engagement with safety.

## Are There Any Data About the Effect of Context on Effectiveness?

As noted above, McGukin14 recorded the frequency with which patients asked various members of the care team about their HH practices; however, this outcome was not linked to any model about how the outcome might be affected by the context in which the intervention was implemented.

## Conclusions and Comment

Patient and family engagement is an emerging area in patient safety research, with few published effectiveness studies. However, it is an important part of key organizations' patient safety initiatives, and a number of recent studies have described implementation approaches and challenges. Future work must address basic and applied concerns across the spectrum of conceptual foundations and experimental design, including the research questions that need to be answered: the definition and measurement of patient and family engagement; the safety endpoints that should be addressed; and methodological issues around study design.

Also important to address in future work is the variety of approaches that have been taken to promoting patient engagement, whether as an independent intervention or as part of an intervention focused on an existing patient safety practice. Distinguishing the features of “instrumental” patient engagement and “independent” patient engagement interventions will help clarify the nature of patient engagement as a patient safety practice. A summary table is located below (Table 6).

Table 6, Chapter 32 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common | Emerging practice (few studies available) | Uncertain | Low | Little/Moderate

## References

1 The Joint Commission. Advancing Effective Communication, Cultural Competence, and Patient- and Family-Centered Care: A Roadmap for Hospitals. Oakbrook Terrace, IL. The Joint Commission. 2010.
2 Davis RE, Jacklin R, Sevdalis N, Vincent CA. Patient involvement in patient safety: what factors influence patient participation and engagement?. Health Expect. 2007;10(3):259-67. [pmid: 17678514].
3 Entwistle VA. Differing perspectives on patient involvement in patient safety. Qual Saf Health Care. 2007;16(2):82-3. [pmid: 17403749].
4 Koutantji M, Davis R, Vincent C, Coulter A. The patient's role in patient safety: engaging patients, their representatives, and health professionals. Clinical Risk. 2005;11:99-104.
5 Vincent CA, Coulter A. Qual Saf Health Care. Patient safety: what about the patient?. 2002;11:76-80. [pmid: 12078376].
6 Perneger T. The Council of Europe recommendation Rec(2006)7 on management of patient safety and prevention of adverse events in health care. Int J Qual Health Care. 2008;20(5):305-7. [pmid: 18718952].
7 Schwappach DL. Med Care Res Rev. Review: engaging patients as vigilant partners in safety: a systematic review. 2010;67:119-48. [pmid: 19671916].
8 Longtin Y, Sax H, Leape LL, Sheridan SE, Donaldson L, Pittet D. Patient participation: current knowledge and applicability to patient safety. Mayo Clin Proc. Jan. 2010;85(1):53-62. [pmid: 20042562].
9 Lyons M. Qual Saf Health Care. Should patients have a role in patient safety? A safety engineering view. 2007;16:140-2. [pmid: 17403763].
10 Hall J, Peat M, Birks Y, et al. Qual Saf Health Care. Effectiveness of interventions designed to promote patient involvement to enhance safety: a systematic review. 2010;19:e10. [pmid: 20427301].
11 Peat M, Entwistle V, Hall J, Birks Y, Golder S. J Health Serv Res Policy. Scoping review and approach to appraisal of interventions intended to involve patients in patient safety. Suppl 1. 2010;15:17-25. [pmid: 20075123].
12 King A, Daniels J, Lim J, Cochrane DD, Taylor A, Ansermino JM. Qual Saf Health Care. Time to listen: a review of methods to solicit patient reports of adverse events. 2010;19:148-57. [pmid: 20351164].
13 Weingart SN, Toth M, Eneman J, et al. Int J Qual Health Care. Lessons from a patient partnership intervention to prevent adverse drug events. 2004;16:499-507. [pmid: 15557360].
14 McGuckin M, Taylor A, Martin V, Porten L, Salcido R. Am J Infect Control. Evaluation of a patient education model for increasing hand hygiene compliance in an inpatient rehabilitation unit. 2004;32:235-8. [pmid: 15175621].
15 Stone S, Slade R, Fuller C, et al. Journal of Hospital Infection. Early communication: Does a national campaign to improve hand hygiene in the NHS work? Initial English and Welsh experience from the NOSEC study (National Observational Study to Evaluate the CleanYourHandsCampaign). 2007;66:293-6. [pmid: 17582651].
16 McGuckin M, Waterman R, Storr IJ, et al. Evaluation of a patient-empowering hand hygiene programme in the UK. J Hosp Infect. 2001;48(3):222-7. [pmid: 11439010].
17 McGuckin M, Storr J, Longtin Y, Allegranzi B, Pittet D. Patient empowerment and multimodal hand hygiene promotion: a win-win strategy. Am J Med Qual. 2011;26(1):10-7. [pmid: 20576998].
18 Ray EM, Smith R, Massie S, et al. Family alert: implementing direct family activation of a pediatric rapid response team. Jt Comm J Qual Patient Saf. 2009;35(11):575-80. [pmid: 19947334].
19 Dean BS, Decker MJ, Hupp D, Urbach AH, Lewis E, Benes-Stickle J. Condition HELP: a pediatric rapid response team triggered by patients and parents. J Healthc Qual. 2008;30(3):28-31. [pmid: 18507237].
20 Gerdik C, Vallish RO, Miles K, Godwin SA, Wludyka PS, Panni MK. Successful implementation of a family and patient activated rapid response team in an adult level 1 trauma center. Resuscitation. 2010;81(12):1676-81. [pmid: 20655645].
21 Krauss MJ, Tutlam N, Costantinou E, Johnson S, Jackson D, Fraser VJ. Intervention to prevent falls on the medical service in a teaching hospital. Infect Control Hosp Epidemiol. 2008;29(6):539-45. [pmid: 18476777].
22 van Gaal BG, Schoonhoven L, Mintjes JA, et al. Int J Nurs Stud. Fewer adverse events as a result of the SAFE or SORRY? programme in hospitals and nursing homes. Part I: Primary outcome of a cluster randomised trial. 2011;48:1040-8. [pmid: 21419411].
23 Garnerin P, Ares M, Huchet A, Clergue F. Verifying patient identity and site of surgery: improving compliance with protocol by audit and feedback. Qual Saf Health Care. 2008;17(6):454-8. [pmid: 19064662].
24 Nilsson L, Lindberget O, Gupta A, Vegfors M. Implementing a pre-operative checklist to increase patient safety: a 1-year follow-up of personnel attitudes. Acta Anaesthesiol Scand. 2010;54(2):176-82. [pmid: 19719811].
25 Owers C, Lees E, Roberts J. Correct site surgery - Are we up to standard?. CentEurJMed. Aug. 2010;5(4):407-10.
26 DiGiovanni CW, Kang L, Manuel J. Patient compliance in avoiding wrong-site surgery. J Bone Joint Surg Am. 2003;85-A(5):815-9. [pmid: 12728030].
27 Bergal LM, Schwarzkopf R, Walsh M, Tejwani NC. Patient participation in surgical site marking: can this be an additional tool to help avoid wrong-site surgery?. J Patient Saf. 2010;6(4):221-5. [pmid: 21500609].
28 Coleman EA, Smith JD, Frank JC, Min SJ, Parry C, Kramer AM. Preparing patients and caregivers to participate in care delivered across settings: the Care Transitions Intervention. J Am Geriatr Soc. 2004;52(11):1817-25. [pmid: 15507057].
29 Coleman EA, Parry C, Chalmers SA, Chugh A, Mahoney E. The central role of performance measurement in improving the quality of transitional care. Home Health Care Serv Q. 2007;26(4):93-104. [pmid: 18032202].
30 Parry C, Min SJ, Chugh A, Chalmers S, Coleman EA. Further application of the care transitions intervention: results of a randomized controlled trial conducted in a fee-for-service setting. Home Health Care Serv Q. 2009;28(2-3):84-99. [pmid: 20182958].
31 Voss R, Gardner R, Baier R, Butterfield K, Lehrman S, Gravenstein S. The care transitions intervention: translating from efficacy to effectiveness. Arch Intern Med. 2011;171(14):1232-7. [pmid: 21788540].
32 Parrish MM, O'Malley K, Adams RI, Adams SR, Coleman EA. Implementation of the care transitions intervention: sustainability and lessons learned. Prof Case Manag. 2009;14(6):282-93. quiz 294-5. [pmid: 19935345].
33 Parry C, Kramer HM, Coleman EA. A qualitative exploration of a patient-centered coaching intervention to improve care transitions in chronically ill older adults. Home Health Care Serv Q. 2006;25(3-4):39-53. [pmid: 17062510].