# Ensuring Documentation of Patients' Preferences for Life-Sustaining Treatment: Brief Update Review

## Introduction

Numerous studies have documented that the care patients receive at the end of life is often not consistent with their preferences. In addition, communication about end-of-life issues is suboptimal, and advance directive completion and documentation of health care proxies and preferences for life-sustaining treatment often does not occur. For example, a study of advanced cancer patients who died in one hospital and cancer center1 found that only 19 percent of patients had documentation of an advance directive or a surrogate decisionmaker in the medical record. Furthermore, only one of the 17 patients who received mechanical ventilation had documentation of preferences regarding mechanical ventilation or documentation of why this information was unavailable. Other research has found that a majority of physicians whose patients had advance directives were not aware of them, that having an advance directive did not increase medical record documentation of patient preferences, and that advance directives were often not used in medical care.2

These gaps in quality can have several consequences. They can lead to patients receiving care that is not consistent with their preferences: lack of appropriate documentation or other miscommunication about the appropriate application of Do Not Resuscitate (DNR) orders or a patient's desire to not receive aggressive care at the end of life can lead to errors of providing invasive treatments, such as intubation and resuscitation, that are inconsistent with patient preferences and can lead to significant patient and family suffering. Poor documentation or communication about these preferences can also lead to confusion among staff, miscommunication with families, and errors in code situations. Significant harm may result if a patient's health care proxy is not documented or not followed, or if end-of-life decisions are made with a surrogate who was not the patient's surrogate of choice.

The original “Making Health Care Safer” report reviewed interventions aimed at increasing individuals' communication of their preferences for end-of-life care, through completion of either advance directives or health care powers of attorney. This review found that although policies to facilitate and increase rates of completion of such instruments completed are widespread, evidence was lacking that these instruments actually improve compliance with patients' end-of-life care wishes. Based on a recent systematic review that we conducted on the impact of quality improvement interventions on end-of-life care, this chapter updates the review of interventions aimed at improving completion of advance directives, as well as interventions to increase general communication about preferences and care at the end of life, and examines evidence that communication or advance directives increase the likelihood that patients' end-of-life care preferences are followed.3

## What Is the Practice of Ensuring Documentation of Life-Sustaining Treatment?

Ensuring documentation of preferences regarding life-sustaining treatment is included as one element of the 2010 Update of the National Quality Forum's 34 “Safe Practices for Better Healthcare.” This patient safety practice (PSP) is described as follows4:

Ensure that written documentation of the patient's preferences for life-sustaining treatments is prominently displayed in his or her chart…Organization policies, consistent with applicable law and regulation, should be in place and address patient preferences for life-sustaining treatment and withholding resuscitation…. The definition of life-sustaining treatment may include, but is not limited to, mechanical ventilation, renal dialysis, chemotherapy, antibiotics, and artificial nutrition and hydration.

As conceptualized by the National Quality Forum and Joint Commission, this PSP focuses on encouraging advance directive completion and documentation in patients' medical records. Advance directives can document patients' wishes about life-sustaining treatment (the living will), choice of a surrogate decisionmaker (the durable power of attorney), or both. Advance directives have many drawbacks, including frequent lack of applicability to decisions about life-sustaining treatment until patients are incapacitated and close to death, imprecise language, and lack of translation into medical care, such as DNR orders. Therefore, this practice has become more broadly conceptualized as advance care planning, defined as a process of communication between a patient, family/health care proxy, and health care providers for the purpose of identifying a surrogate decision-maker, clarifying treatment preferences, and developing individualized goals of care about life-sustaining and other aggressive treatments. It can also include ensuring appropriate communication about and completion of Do Not Resuscitate orders when consistent with patients' preferences; documentation practices to ensure that these orders are followed when present; and newer forms of documentation to ensure that preferences are honored across settings, such as POLST (Physician Orders for Life-Sustaining Treatment) and similar programs (described below).

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

A variety of interventions intended to improve end-of-life care of include improving care planning as part of the intervention, such as palliative care services in hospitals and case management. Descriptions of implementation and effectiveness of key policy initiatives are described below.

In the United States, the Patient Self-Determination Act, passed by Congress in 1990, requires that patients are given written notice upon admission to a variety of health care institutions of their decision-making rights and policies regarding advance health care directives. Although it is unclear if implementation of this legislation improved rates of advance directive completion or elicitation of patient preferences, several expanding programs are improving implementation of advance care planning at the community or state level. A program to promote and implement advance care planning processes across an entire community, The Respecting Choices program in Lacrosse, Wisconsin, (http://respectingchoices.org/),5 has achieved nearly universal advance directive completion in the community, although no rigorous research to document the impact of this initiative on end-of-life care in the community was identified in our systematic review.3.

POLST (Physician Orders for Life-Sustaining Treatment) (www.ohsu.edu/polst/)6 is an initiative to document patients' preferences on an order form that is accepted across all settings of care. Similar initiatives have been endorsed in at least 10 U.S. States. In our systematic review, we did not find any evaluations of POLST or similar initiatives on the hospital or community level that met our inclusion criteria of enrolling a comparison group.3

The Gold Standards Framework (www.goldstandardsframework.org.uk)7 is a systematic approach for improving care at the end of life that has been widely implemented in primary care practices, nursing homes, hospitals, and other settings throughout the United Kingdom. This approach includes goals of increasing the percentage of patients with advance care planning discussions and increasing concordance between patient preferences and care at the end of life. In our systematic review,3 we identified one evaluation with patient-centered outcomes, a 2009 non-randomized trial8 addressing symptoms, needs, and coordination in 49 nursing homes, that found statistically significant reductions in nursing home deaths and in crisis hospitalizations.

The Liverpool Care Pathway (www.liv.ac.uk/mcpcil/liverpool-care-pathway/)9 is a template for structuring care at the end of life, including communication and documentation about which treatments are appropriate. Programs based on this template have been implemented in a variety of settings and countries, including the United Kingdom, Australia, and the Netherlands. In our systematic review,3 we identified one evaluation, a 2010 non-randomized trial, which evaluated the Liverpool Care Pathway in a variety of settings, including hospitals, nursing homes, residential facilities, and home care in the Netherlands. The intervention did not statistically significantly increase use of do-not resuscitate orders at the end of life, possibly because sample sizes were small.10

## What Have We Learned About Documenting Life-Sustaining Treatments?

The issue of documentation of life-sustaining treatment was addressed in the 2001 Making Health Care Safer report, as Advance Planning for End-of-Life Care. That review discussed early studies on the POLST and Respecting Choices initiatives (described above) as well as several studies of improving rates of advance directive completion.

More recent systematic reviews have found that interventions can significantly increase rates of advance directive completion. However, these reviews have found few studies on the actual impact of documentation of preferences for life-sustaining treatment such as advance directives on patient outcomes, and have concluded that the few studies that have been conducted have not generally found a significant impact.11,12

In a systematic review of the literature from 2000 through March 2011, we addressed quality improvement interventions for end-of-life care, including the target of communication.3 We included prospective studies with a comparison group, enrolling patients with serious or advanced illness who were unlikely to recover or be cured, and assessing patient-centered outcomes, including quality of care and health care utilization.

For the target of communication, we did not identify any studies addressing this practice specifically (i.e., the impact of increasing or improving documentation of life-sustaining treatment preferences on improved outcomes or decreased errors). However, we did identify a number of studies focusing on increasing and improving end-of-life communication more generally, primarily in the intensive care unit setting. These studies included quality improvement interventions to increase the frequency and/or structure of family meetings to address these issues, and the use of palliative care and ethics consultants. Fifteen studies (6 RCTs, 9 non-RCTs) evaluated health care utilization, such as intensive care unit length of stay, as an outcome. We found moderate strength of evidence to support the impact of interventions on this outcome: 73% of studies found a statistically significant improvement in the intervention compared with the control group.

Observational studies have shown that patients with advance directives or related documents are more likely to receive care consistent with their preferences. A retrospective evaluation of the care provided for residents with POLST orders found that care provided was consistent with residents' preferences 98% of the time for resuscitation and 94% overall.13 Another retrospective analysis of survey data found that patients who died with advance directives received care strongly aligned with their preferences (97% of those who requested comfort care received it). Subjects with living wills or who had a health care proxy were statistically significantly less likely to receive aggressive care than those without advance directives.14 Patients who had discussions about prognosis and end-of-life care with their providers also had care at the end of life that was less invasive and more consistent with their preferences.

## Conclusions and Comment

Achieving concordance between patients' end-of-life care preferences and the care that they receive is an accepted goal in health care, and improving communication about and documentation of patients' preferences is important. Errors such as resuscitation in a patient who wanted comfort care because the correct documentation had not been completed can cause significant harm and suffering for patients and families.

Recent systematic reviews have found moderate strength of evidence that interventions can improve rates of advance directive completion and that interventions to improve end-of-life communication can reduce health care utilization, which may be a marker for overly aggressive care, at the end of life. However, insufficient evidence exists to support whether advance directives or current policy initiatives to improve documentation of care preferences across settings, such as POLST in the United States, improve the likelihood that patients receive care consistent with their preferences at the end of life. Interventions to improve communication about end-of-life care issues should be implemented in hospitals, particularly in the intensive care unit settings. Emerging types of interventions, such as initiatives present in some hospitals for requirements for code status or health care proxy documentation for all patients upon admission or other initiatives to improve documentation of care preferences, deserve further evaluation. A summary table is following (Table 1).

Table 1, Chapter 30 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate | Moderate | Low | Low | Moderate/Moderate

## References

1 Dy SM, Lorenz KA, O'Neill SM, et al. Cancer Quality-ASSIST supportive oncology quality indicator set: feasibility, reliability, and validity testing. Cancer. 2010;116(13):3267-75. [pmid: 20564637].
2 Kass-Bartelmes BL, Hughes R. Advance care planning: preferences for care at the end of life. J Pain Palliat Care Pharmacother. 2004;18(1):87-109. [pmid: 15148012].
3 Dy SM, Aslakson R, Wilson RF, et al. Improving Health Care and Palliative Care for Advanced and Serious Illness. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report No. 208. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 12(13)-E014-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012.
4 National Quality Forum. Safe Practices for Better Healthcare 2010 Update: A Consensus Report. www.qualityforum.org/Projects/Safe_Practices_2010.aspx.
5 Gundersen Lutheran Medical Center. Respecting Choices. 2011. http://respectingchoices.org/.
6 Oregon Health Sciences University. Pysician Orders for Life-sustaining Treatement Paradigms (POLST). 2008. www.ohsu.edu/polst/.
7 National Gold Standards Framework Centre. www.goldstandardsframework.org.uk/.
8 Mazzocato C, Michel-Nemitz J, Anwar D, Michel P. The last days of dying stroke patients referred to a palliative care consult team in an acute hospital. Eur J Neurol. 2010;17(1):73-7. [pmid: 19614968].
9 The Marie Curie Palliative Care Institute. Liverpool Care Pathway for the Dying Patient (LCP). www.liv.ac.uk/mcpcil/liverpool-care-pathway/.
10 van der Heide A, Veerbeek L, Swart S, van der Rijt C, van der Maas PJ, van Zuylen L. End-of-life decision making for cancer patients in different clinical settings and the impact of the LCP. J Pain Symptom Manage. 2010;39(1):33-43. [pmid: 19892509].
11 Lorenz KA, Lynn J, Dy SM, et al. Evidence for improving palliative care at the end of life: a systematic review. Ann Intern Med. 2008;148(2):147-59. [pmid: 18195339].
12 Walling A, Lorenz KA, Dy SM, et al. Evidence-based recommendations for information and care planning in cancer care. J Clin Oncol. 2008;26(23):3896-902. [pmid: 18688058].
13 Hickman SE, Nelson CA, Moss AH, Tolle SW, Perrin NA, Hammes BJ. The consistency between treatments provided to nursing facility residents and orders on the physician orders for life-sustaining treatment form. J Am Geriatr Soc. 2011;59(11):2091-9. [pmid: 22092007].
14 Silveira MJ, Kim SY, Langa KM. Advance directives and outcomes of surrogate decision making before death. N Engl J Med. 2010;362(13):1211-8. [pmid: 20357283].