# High-Alert Drugs: Patient Safety Practices for Intravenous Anticoagulants

## How Important Is the Problem?

High-alert medications are defined as medications that are the most likely to cause significant patient harm, even when used correctly. These medications are more likely to be associated with harm due to issues such as narrow therapeutic ranges (increasing the potential for a prescribing error), and also cause more significant harm when an error does occur because of the significant nature of the potential adverse effects such as bleeding or hypoglycemia.1,2 Many of these medications are also more likely to be associated with dosing errors, due to issues such as the need to frequently calculate dosing based on weight. A study evaluating adverse drug events found that high-alert medications accounted for 48 percent of the events.3

The Institute of Safe Medical Practices identifies the top high-alert medications to be insulin, opioids, injectable potassium chloride (or phosphate), intravenous anticoagulants (heparin), and sodium chloride solutions above 0.9 percent, due to both common use and significance of associated harm.1 Other high-alert medications include chemotherapeutic agents and sedatives.

From 1997 to 2007, 9.3 percent of all hospital sentinel events were medication-related, and anticoagulants made up 7.2 percent of medication events. Unfractionated heparin was the anticoagulant most frequently involved in these events.4 Administration errors (e.g., dosing and timing), omission, and prescribing errors constituted approximately 70 percent of heparin errors.5

## What Is the Patient Safety Practice?

In the 2001 “Making Health Care Safer report,” this PSP was conceptualized as “Protocols for High-Risk Drugs: Reducing Adverse Drug Events Related to Anticoagulants.”6 The rationale for focusing on anticoagulants was that, although a number of other classes of medications have been identified as “high-risk,” and some recommendations to reduce risks apply to multiple classes of medications, the effectiveness of interventions to reduce risks associated with other medications have not been as extensively evaluated as interventions to reduce risks associated with heparin. Because interventions to reduce adverse events may differ significantly by drug type, and the focus on anticoagulants in the inpatient setting is mainly on heparin, this review focused on heparin, the most commonly used intravenous anticoagulant, as an illustrative example rather than addressing issues for high-alert medications overall.

The original report reviewed two types of interventions for heparin:

- The implementation of dosing protocols or nomograms, which normally include standard initial doses and instructions for monitoring and adjusting doses
- Inpatient anticoagulation services, which provide pharmacist input on dosing and monitoring

Weight-based nomograms use actual patient body weight to calculate an optimum dose that is patient-specific. In contrast, physician dosing without nomograms often does not account accurately for patient characteristics.

This current report systematically reviewed the literature to identify effectiveness studies of any intervention with a goal to reduce adverse events related to intravenous heparin in the inpatient setting that had a comparison group and was not a qualitative study. Since this PSP is currently most often conceptualized as focusing on intravenous administration as the most high-risk route, we did not include subcutaneous or oral anticoagulant administration in this review. Intravenous anticoagulants are particularly high risk because dosing is complex and the therapeutic range is particularly narrow. This narrow range increases the opportunity for harm.6-9 Although bleeding can occur even at therapeutic doses of heparin, it is much more likely when the dose is excessive or inadequately monitored. Unfractionated heparin, which is given intravenously, is widely used as the drug of choice for a variety of clinical conditions where rapid and closely monitored anticoagulation is needed, such as acute coronary syndromes.10 However, since the 2001 publication of “Making Health Care Safer,” low-molecular-weight heparins—which have a less complex dosing regimen, are given subcutaneously, and have been shown to have equivalent efficacy for many indications—have widely replaced unfractionated heparin for some clinical conditions such as venous thromboembolism (VTE) prophylaxis.

A wide variety of safety practices are recommended to increase patient safety for intravenous anticoagulants in general. These practices include limiting the number and dosage of high alert drugs prescribed (to ensure that only patients who are most likely to benefit receive the medications or that lower-risk options are used whenever possible), having independent system checks and balances in place to identify and prevent dosing errors, and having a transparent error reporting system to aid in the development and implementation of system changes.1,2 Other practices include removing high-alert medications from nursing units and floor stock, standardizing medication doses, using single doses or pre-mixed solutions, labeling different strength solutions clearly to avoid mixups (e.g., Heplock packaging), provider education and drug-administration protocols and decision support tools that involve double-checking of the drug and dosing, pump-setting, and dosage.4 Health information technology tools may help reduce errors associated with high-alert medications by preventing significant overdoses (e.g. tenfold errors in dosing) and verifying that the correct medication is being administered.11,12 However, the level of effectiveness of health information technology may vary.13,14 Specific heparin patient-safety practices reviewed here include dosing nomograms and weight-based dosing interventions, with and without the use of health information technology tools as part of the intervention.

## Why Should This Patient Safety Practice Work?

Numerous patient factors, particularly patient weight, can influence the dosing needs for heparin. Bleeding risk increases as the dose increases and with inappropriately high dosing. Patients on intravenous heparin have multiple risk factors for bleeding that may also affect dosing needs: they often have high acuity conditions such as recent stroke, or are undergoing high-risk procedures such as coronary artery bypass or continuous hemodialysis. In addition, dosing ranges for heparin vary by indication; physicians often tend to be conservative and underdose heparin when not using standard nomograms.10 For these reasons, standardization of dosing and monitoring of subsequent anticoagulation are vital.

Heparin-induced adverse effects not related to dosing issues (e.g., heparin-induced thrombocytopenia) are also important considerations in heparin use, but are not generally considered patient safety events and were not included in the scope of this review.

## What Are the Beneficial Effects of the Patient Safety Practice?

The original “Making Health Care Safer” report6 found six studies, mostly of low quality, on heparin nomograms. All showed a statistically significant improvement in time to achievement of, or proportion of patients with, appropriate anticoagulation. Two low-quality studies of inpatient anticoagulation services also showed statistically significant improvements in anticoagulation. All studies either did not evaluate bleeding outcomes or did not have a sufficient sample size to measure these outcomes. Four of the six studies of nomograms did show a statistically significant increase in the proportion of patients with partial thromboplastin time (PTT) values above the normal range (and therefore at increased risk for over-anticoagulation and bleeding complications).

For this review, a total of 1,960 unique abstracts were captured by the search strategy. Of these, 1,936 were excluded during the abstract screening phase. Seven articles met the inclusion criteria for intervention studies evaluating the effectiveness of interventions to improve the safety of intravenous heparin administration, published after the “Making Health Care Safer” report (Table 1). We did not identify any additional recent systematic reviews of high-alert medications or heparin. We identified five studies evaluating the use of weight-based nomograms, all published between 2001 and 2005. The only randomized, controlled trial was by Toth and colleagues, who developed a weight-based nomogram for heparin dosing in transient ischemic attack (TIA) and/or stroke.15 Out of 206 patients, total complications were significantly reduced using the nomogram (9 pre [8.5%] vs. 2 post [2%] p=0.04). Additionally, time to supratherapeutic activated PTT (aPTT) (i.e., adequate anticoagulation) was reduced (1.1 with nomogram vs. 1.6 without nomogram; p=0.01) and time to therapeutic-range aPTT (i.e., therapeutic anticoagulation) was reached with fewer adjustments (18 with the intervention vs. 13 for the control group; p<0.01). Zimmermann and colleagues also used a pre-post design to assess the effect of a weight-based nomogram for 173 patients with acute coronary syndromes.16 Median time to first therapeutic aPTT was reduced from >24 to 8.75 hours (p<0.001) and the mean number of aPTT tests decreased from 4.15 (SD.83) to 3.62(SD.85) (p=0.002). Oyen and colleagues conducted a pre-post study of 419 patients evaluating the implementation of a computerized nomogram for acute coronary syndromes targeted at nurses and found improvements in anticoagulation outcomes (percentage of a PTT in goal range 44% with the nomogram vs. 27% without); data on complications were not reported. Baird and colleagues17 used a pre-post study design in a small patient sample (n=68) to test an evidence-based nomogram that was developed with a team of nurses, doctors, and a pharmacist; no statistics were reported. Finally, Fraipont et al developed a nurse-directed weight-based nomogram in a very small study (total n=38); the study found that there were no statistically significant differences in anticoagulation outcomes or complications between the intervention and control groups.18

Table 1, Chapter 3 Summary table—heparin effectiveness studies

Author, Year | Description of PSP | Study Design | Outcomes: Benefits
Baird, 2001^17^ | Single protocol for heparin administration | Pre-post | Dosing and time to anticoagulation: No statistics reported
Fanikos, 2007^14^ | Smart pump; drug library with point-of-care decision support; programmable alert | Pre-post | Anticoagulation medication errors: No significant differences
Fraipont, 2003^18^ | Nurse-directed weight-based nomogram | Pre-post | Time to therapeutic anticoagulation, complications: not significant
Oyen, 2005^19^ | Computerized nomogram for acute coronary syndromes | Pre-post | Therapeutic anticoagulation significantly improved, complications not reported
Prusch, 2011^13^ | Intelligent infusion devices (IIDs), bar-code-assisted medication administration system, and electronic medication administration record system | Pre-post | Telemetry drug library monthly compliance and manual pump edits: Statistically significant improvement
Toth, 2002^15^ | Weight-based nomogram for transient ischemic attack and/or stroke | RCT | Total complications, overanticoagulation, time to anticoagulation – all statistically significant improvement
Zimmermann, 2003^16^ | Weight-based nomogram for acute coronary syndromes | Pre-post | Time to anticoagulation significant; complications not significant

The remaining two, more recent, papers assessed the impact of technology along with processes and procedures for the use of the technology on heparin administration safety. A 2011 study by Prusch and colleagues aimed to improve medication safety through the use of intelligent infusion devices (IIDs), a bar-code-assisted medication administration system, and an electronic medication administration record system using a pre-post design. Monthly compliance with the telemetry drug library increased from 56.5 percent (SD: 1.5%) pre-intervention to 72.1 percent (SD: 2.1%) post-intervention (p<0.001), and the number of telemetry manual pump edits decreased (56.9 [SD: 12.8] to 14.7 [SD: 3.9]; p<0.001).13 Finally, Fanikos and colleagues assessed the impact of a smart infusion device with a hospital-determined drug library and programmable software on anticoagulation errors using a pre-post design. After reviewing a total of 14,012 administered doses of heparin in 3,674 patients, the software generated a total of 501 heparin alerts in 246 patients. No significant difference in anticoagulation errors was found as a result of the intervention (49 pre- vs. 48 post-intervention).14

In terms of evidence grading, the strength of evidence for this topic was low. Risk of bias was high due to study design issues: Only one study was an RCT.14 Results were inconsistent, with half of the studies reporting no statistically significant findings; several studies were too small to measure outcomes meaningfully. Many studies did not report patient safety outcomes, but instead reported the outcomes for process measures such as time to therapeutic anticoagulation or compliance with a drug library; many studies that did report complications or errors did not have sufficient sample size. Finally, regarding precision, a number of different outcome measures were used, so no conclusions could be made (see Evidence Table on risk of bias in Appendix D).

## What Are the Harms of the Patient Safety Practice?

Neither the original report nor our updated review found studies that reported on harms of the Patient Safety Practice.

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

The effectiveness studies included older studies on weight-based nomograms and anticoagulation services and newer studies on intelligent infusion devices and other electronic medication systems, in various populations and types and sizes of hospitals (e.g., community and teaching). One United States study from 2000 that evaluated the use of a weight-based nomogram found that utilization was extremely low at approximately 10 percent. Further, utilization was not improved after an intervention that included education as well as configuring the computerized order entry system to allow physicians to choose either the weight-based nomogram, or traditional heparin ordering.20

## Are There Any Data About Costs?

Implementation of heparin nomograms is feasible, although institutions often develop their own systems rather than adapting existing nomograms. The original report found one study that concluded that the costs of frequent monitoring were offset by the reduction in the number of heparin boluses required.6 One of the nomogram studies identified in our update search16 found a statistically significant decrease in the number of monitoring blood tests required, which would reduce the costs to manage patient care.

## Are There Any Data About the Effect of Context on Effectiveness?

Data regarding the impact of context on effectiveness is limited. The evidence found in the studies mentioned above could be divided into three categories: leadership, organizational characteristics, and administration tools.

Two studies commented on the impact of leadership on the effectiveness of the intervention. Baird and colleagues reported that leadership was important for protocol development.17 Prusch and colleagues reported that executive sponsorship and oversight as well as the support of the pharmacy and therapeutics committee were key to effectiveness.13

Regarding organizational characteristics, one study cited the impact of a multidisciplinary team and a relationship between the hospital and the intelligent diffusion device vendors on the development of interoperability between systems.13 Another study19 found that a computerized nomogram provided greater levels of standardization than a paper-based form, since the paper-based form was altered by providers more than 50 percent of the time. Additionally, the computerized version was able to provide feedback on patient states, which improved patient monitoring and the evaluation of the nomogram. Therefore, through the implementation of the computerized nomogram, the heparin dosing protocols and monitoring practices were standardized.

Three studies mentioned external implementation tools, but no details of how these implementation tools affected effectiveness (overall effectiveness results are described above in the section on beneficial effects). Prusch and colleagues used new medication administration technology developed with frontline nurses and pharmacists. Historical data were analyzed to ensure the drug library had optimal dosing limits and medications. Finally, the technology was pilot tested prior to implementation.13 Fanikos and colleagues used the software in the smart infusion device to establish limits for rates programmed into the.14 Fraipont and colleagues used the previously developed Raschke nomogram21 in their study.18

Finally, we identified one additional study which did not meet our inclusion criteria for reporting effectiveness data but took a broader human factors approach to improving heparin safety by improving administration. Harder and colleagues evaluated the human factors associated with improving the safety of heparin administration.22 After completing interviews with the staff, the authors offered suggestions for improving the heparin administration process in order to make the computerized heparin dosing interface more user-friendly (e.g., automatically converting English and metric measurements.) Iterative refinements were made to the system after the initial modifications, and an educational program was rolled out to inform providers about the new heparin administration process.22

## Conclusions and Comment

In conclusion, we found low strength of evidence that patient safety practices, including nomograms and new intelligent medication administration, dosing, and monitoring technology, can improve outcomes for the use of intravenous heparin (Table 2). Through our systematic review, we identified no studies of nomograms published after 2005 and no studies of inpatient anticoagulation services published since 2000, although both the use of protocols (e.g., computerized order entry) and indications for heparin have changed dramatically since that time including concerns regarding dosing in obese patients.23 Only two studies evaluated new technology, and no studies evaluated other types of interventions to improve heparin safety. Study quality was generally low, and many studies had small sample sizes, usually insufficient for the detection of the impact of interventions on complications of heparin administration. We did not identify any studies evaluating the harms of these patient safety practices, although there could be some potential harm from errors caused by misunderstanding of protocols or miscommunication with anticoagulation services, which could also lead to errors in dosing.

Table 2, Chapter 3 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate | Low | Low-to-moderate | Low | Little/Moderate

Although the standardization of dosing protocols, accomplished with the input of front-line personnel, is an important component of increasing safety and has been shown to improve the effectiveness of heparin administration, few studies have evaluated these protocols and had sufficient sample size for patient safety outcomes. Significant barriers also exist to implementing these protocols, and no studies have demonstrated the impact of interventions to increase their use by health care providers. Only a few, small, low-quality studies evaluated other types of interventions to improve the safety of inpatient anticoagulation, such as human factors, anticoagulation services, or new technology, such as computerized order entry or intelligent infusion devices. Because intravenous anticoagulants are one of the most common sources of patient harm from safety issues with high-alert drugs, research on interventions to improve their safety should be a priority. Further study is needed to evaluate the implementation, effectiveness, and context factors for patient safety practices for intravenous heparin, especially in regards to use of new technological tools.

## References

1 The Institute of Safe Medical Practices. ISMP's List of High Alert Medications. 2012. www.ismp.org/tools/highalertmedications.pdf. January 31, 2012.
2 Institute for Healthcare Improvement. High-Alert Medication Safety. www.ihi.org/explore/HighAlertMedicationSafety/Pages/default.aspx. December 13, 2011.
3 Winterstein AG, Hatton RC, Gonzalez-Rothi R, Johns TE, Segal R. Identifying clinically significant preventable adverse drug events through a hospital's database of adverse drug reaction reports. Am J Health Syst Pharm. 2002;59(18):1742-9. [pmid: 12298112].
4 Joint Commission. Preventing Errors related to commonly used anticoagulants. September. 24. 2008;(41). www.jointcommission.org/sentinel_event_alert_issue_41_preventing_errors_relating_to_commonly_used_anticoagulants/. December 5, 2011.
5 Santell JP. Medication Errors Involving Heparin: Findings from a National Reporting Program. Schneider PJ, editor. Improving Heparin Safety. Proceedings from The Ninth Conference CareFusion Center for Safety and Clinical Excellence. March 13-14, 2008. San Diego, CA. www.carefusion.com/safety-clinical-excellence/conferences/ninth-invited-conference.aspx. October 13, 2011.
6 Gandhi TK, Shojania KG, Bates DW. Chapter 9. Protocols for High-Risk Drugs: Reducing Adverse Drug Events Related to Anticoagulants. Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report/Technology Assessment No. 43. (Prepared by the University of California at San Francisco–Stanford Evidence-based Practice Center under Contract No. 290-97-0013.) AHRQ Publication No. 01-E058. Rockville, MD. Agency for Healthcare Research and Quality. July. 2001. www.effectivehealthcare.ahrq.gov.
7 Hirsh J, Anand SS, Halperin JL, Fuster V. AHA Scientific Statement: Guide to anticoagulant therapy: heparin: a statement for healthcare professionals from the American Heart Association. Arterioscler Thromb Vasc Biol. 2001;21(7):E9-9. [pmid: 11451763].
8 Wells PS, Holbrook AM, Crowther NR, Hirsh J. Interactions of warfarin with drugs and food. Ann Intern Med. 1994;121(9):676-83. [pmid: 7944078].
9 Holbrook AM, Pereira JA, Labiris R, et al. Systematic overview of warfarin and its drug and food interactions. Arch Intern Med. 2005;165(10):1095-106. [pmid: 15911722].
10 Hirsh J, Raschke R. Heparin and low-molecular-weight heparin: the Seventh ACCP Conference on Antithrombotic and Thrombolytic Therapy. Chest. 2004;126(3 Suppl):188S-203S. [pmid: 15383472].
11 Poon EG, Keohane CA, Yoon CS, et al. Effect of bar-code technology on the safety of medication administration. N Engl J Med. 2010;362(18):1698-707. [pmid: 20445181].
12 Keohane CA, Hayes J, Saniuk C, et al. Intravenous medication safety and smart infusion systems: lessons learned and future opportunities. J Infus Nurs. 2005;28(5):321-8. [pmid: 16205498].
13 Prusch AE, Suess TM, Paoletti RD, et al. Integrating technology to improve medication administration. Am J Health Syst Pharm. 2011;68(9):835-42. [pmid: 21515868].
14 Fanikos J, Fiumara K, Baroletti S, et al. Impact of smart infusion technology on administration of anticoagulants (unfractionated Heparin, Argatroban, Lepirudin, and Bivalirudin). Am J Cardiol. 2007;99(7):1002-5. [pmid: 17398201].
15 Toth C, Voll C. Validation of a weight-based nomogram for the use of intravenous heparin in transient ischemic attack or stroke. Stroke. 2002;33(3):670-4. [pmid: 11872885].
16 Zimmermann AT, Jeffries WS, McElroy H, et al. Utility of a weight-based heparin nomogram for patients with acute coronary syndromes. Intern Med J. 2003;33(1-2):18-25. [pmid: 12534874].
17 Baird RW. Quality improvement efforts in the intensive care unit: development of a new heparin protocol. Proc (Bayl Univ Med Cent). 2001;14(3):294-6. discussion 296-8. [pmid: 16369633].
18 Fraipont V, Lambermont B, Moonen M, et al. Annales Francaises d'Anesthesie et de Reanimation: Comparison of a nurse-directed weight-based heparin nomogram with standard empirical doctor-based heparin dosage. Ann Fr Anesth Reanim. Jul. 2003;22(7):591-4. [pmid: 12946490].
19 Oyen LJ, Nishimura RA, Ou NN, et al. Effectiveness of a computerized system for intravenous heparin administration: using information technology to improve patient care and patient safety. Am Heart Hosp J. 2005;3(2):75-81. [pmid: 15860993].
20 Balcezak TJ, Krumholz HM, Getnick GS, et al. Utilization and effectiveness of a weight-based heparin nomogram at a large academic medical center. Am J Manag Care. 2000;6(3):329-38. [pmid: 10977433].
21 Raschke RA, Reilly BM, Guidry JR, et al. The weight-based heparin dosing nomogram compared with a “standard care”nomogram. A randomized controlled trial. Ann Intern Med. 1993;119(9):874-81. [pmid: 8214998].
22 Harder KA, Bloomfield JR, Sendelbach SE, et al. Improving the Safety of Heparin Administration by Implementing a Human Factors Process Analysis. 2005.
23 Barletta JF, DeYoung JL, McAllen K, et al. Limitations of a standardized weight-based nomogram for heparin dosing in patients with morbid obesity. Surg Obes Relat Dis. 2008;4(6):748-53. [pmid: 18586569].