# Medication Reconciliation Supported by Clinical Pharmacists (NEW)

We have specified support by clinical pharmacists in the title for this review, because the evidence for the clinical impact of medication reconciliation exclusively involves interventions in which pharmacists play a key role. We regarded this specification as important since accreditation standards to implement medication reconciliation do not require involvement by pharmacists. Thus, medication reconciliation as implemented in many hospitals may not achieve the same impacts reported in the literature that led to this required practice.

## How Important Is the Problem?

Transitions in care, such as admission and discharge from an acute care hospital or changes in setting within a hospital, place patients at risk for errors due to poor communication and inadvertent information loss. Unintended medication discrepancies represent one well-studied category of such patient safety problems related to information loss at transitions of care.

When patients are admitted to or discharged from a hospital, treating physicians may intentionally make changes to patients' preadmission medication regimens. However, they may also make changes unintentionally (e.g., as the result of not being aware of the full list of preadmission medications or having inaccurate information on the most recent doses). Published studies suggest that 40–54% of patients experience unintentional medication discrepancies upon admission to acute care hospitals.1 Slightly higher rates of unintentional discrepancies may occur during internal hospital transfers (e.g., intensive care unit to ward), and at least 40% of patients experience discrepancies at hospital discharge.2-5 A recent large observational study using population data from Ontario, Canada showed that 187,912 patients admitted to a hospital were at significantly increased risk for unintentional discontinuation of chronic, evidence-based therapies as compared with control patients not admitted to a hospital (n = 208,468).6 Admission to an intensive care unit carried an even greater risk of unintentional discontinuation of these medications.

Not all unintended discrepancies carry substantial risks for harm. In a systematic review of unintended discrepancies at hospital admission, only five of 22 studies estimated the clinical importance of errors in the medication history. The proportion of all discrepancies likely to cause clinical problems, as estimated by these five studies, ranged widely from 11% to 59%.1 The two common categories of unintended discrepancies that contribute to clinical risk are ‘omissions’—key prescription and non-prescription medications are inappropriately not started or continued (range: 46–56% of all discrepancies)—and ‘commissions’—medications that patients have discontinued are inadvertently re-started.1,2,5

## What Is the Patient Safety Practice?

Medication reconciliation is the proposed formal, systematic strategy to overcome medication information communication challenges and reduce unintended medication discrepancies that occur at transitions in care (Figure 1). Ideally, health care providers from different professions (physicians, nurses, pharmacists) work together and with patients (and their families) to ensure the accurate and consistent communication of medication information across transitions in care.

Figure 1, Chapter 25 Overview of medication reconciliation

Adapted from Pharmacy Practice 2009;25(6):26 with permission

Figure 1 provides an overview of the processes of medication reconciliation, defined as a “proposed formal, systematic strategy to overcome medication information communication challenges and reduce unintended medication discrepancies that occur at transitions in care.” The figure shows the four best possible sources of information on a patient's medications (patient/family interview, medication vials or lists, government medication database, and the patient's previous health records), which are combined to form a medication history. To this history is added any medications ordered during hospital admission and/or transfer. At the time of discharge, a medication discharge plan is then formulated and communicated as a reconciled list of discharge prescriptions, a physician discharge summary, and a medication schedule. The figure was adapted, with permission, from Pharmacy Practice 2009; 25(6):26, 2009.

The World Health Organization (WHO) has prioritized medication reconciliation as one of five top patient safety strategies, within the Action on Patient Safety: High 5s.7 National campaigns targeting the reduction of preventable patient adverse events such as the Institute for Healthcare Improvement's “100,000 Lives Campaign” in the United States (U.S.) as well as the Canadian Patient Safety Institute's “Safer Healthcare Now!” have championed medication reconciliation as one of a few core interventions. Furthermore, accreditation authorities such as The Joint Commission in the U.S. and Accreditation Canada made medication reconciliation best practices a mandatory requirement for various health care settings. However, of note, The Joint Commission no longer formally scores medication reconciliation during accreditation surveys, although the latter loosely remains part of the National Patient Safety Goal to “Maintain and communicate accurate patient medication information.”8

The ‘Best Possible Medication History’ (BPMH) constitutes the cornerstone for medication reconciliation. The BPMH is more comprehensive than a routine primary medication history, as it involves “(1) a systematic process for interviewing the patient/family; and (2) a review of at least one other reliable source of information (e.g., review of a central medication database, inspection of medication vials, or contact with the community pharmacy) to obtain and verify patient medications (prescribed and non-prescribed).”9

Some may argue that ambulatory patients face greater risks from medication problems than do patients in a protected hospital setting. Studies of ambulatory reconciliation have begun to appear.10,11 However, most studies of medication reconciliation still focus on the hospital setting, which remains the focus of this review.

## What Are the Beneficial Effects of the Patient Safety Practice?

One previous systematic review12 has summarized the evidence on inpatient medication reconciliation, but this review did not include quantitative synthesis. We sought to quantify the impact of medication reconciliation on unintentional discrepancies with the potential for harm (“clinically significant discrepancies”) and hospital utilization following discharge, as assessed by unplanned emergency visits and readmission to hospital.

To evaluate these impacts of medication reconciliation, we searched major bibliographic databases (MEDLINE, Embase, Cochrane CENTRAL) and scanned article reference lists. Appendix C, Section A and B, present the search strategy, article flow, and methods. Eligible studies reported emergency department visits and hospitalizations within 30 days of discharge or evaluated the severity of clinical significance of unintentional discrepancies. We included randomized controlled trials, before-after evaluations, and post-intervention studies.

All included 18 studies reporting 20 medication reconciliation interventions came from hospitals in the United States or Canada (Table 1). We identified studies with interventions related to medication reconciliation from other countries, but all met pre-specified reasons for exclusion, such as not clearly distinguishing intended from unintended medication discrepancies13-15 and assessment of clinical severity performed solely by personnel conducting medication reconciliation.16,17

Table 1, Chapter 25 Studies of medication reconciliation that include assessment of clinically significant unintended discrepancies and emergency department visits and hospitalizations within 30 days of discharge

Study | Setting | Study Design | Transition Targeted | Additional Interventions Beyond Medication Reconciliation | Outcome
Coffey, 2009^18^ | Pediatric ward in academic medical center in Canada | Prospective post-intervention study (272 patients) | Admission to hospital | None | Clinically significant unintentional discrepancies
Cornish, 2005^2^ | Medical ward in academic medical center in Canada | Prospective post-intervention study (151 patients) | Admission to hospital | None | Clinically significant unintentional discrepancies
Gleason, 2004^19^ | Surgical and medical wards in U.S. academic medical center | Post-intervention study (204 patients, 12 adult medical-surgical units) | Admission to hospital | None | Clinically significant unintentional discrepancies
Gleason, 2010^20^ | Medical ward in U.S. academic medical center | Prospective post-intervention study (651 patients) | Admission to hospital | None | Clinically significant unintentional discrepancies
Kripalani, 2012^21^ | Medical and cardiology wards in two U.S. academic medical centers | RCT (428 patients) | At time of enrollment in study, discharge home, and in-hospital transfer | Discharge counseling | Clinically significant unintentional discrepancies
Kripalani, 2012^21^ | Medical and cardiology wards in two U.S. academic medical centers | RCT (423 patients) | At time of enrollment in study, discharge home, and in-hospital transfer | Pharmacist intervention including in-patient pharmacist counseling, low-literacy adherence aids, and post-discharge phone call | Clinically significant unintentional discrepancies
Lee, 2010^5^ | Inpatient wards and critical care units in two academic medical centers in Canada | Prospective post-intervention study (129 patients, 10 patient care units) | In-hospital transfer | None | Clinically significant unintentional discrepancies
Pippins, 2008^22^ | Medical wards in two U.S. academic medical centers | Prospective post-intervention study (180 patients, 7 medical teams) | Discharge home | None | Clinically significant unintentional discrepancies
Stone, 2010^23^ | Pediatric ward in U.S. academic medical center | Prospective post-intervention study (23 patients on 2 medical teams) | Admission to hospital | None | Clinically significant unintentional discrepancies
Vira, 2006^24^ | Acute care units in urban community hospital in Canada | Retrospective post-intervention study (60 patients) | Admission to hospital; discharge home | None | Clinically significant unintentional discrepancies
Wong, 2008^4^ | Medical ward in academic medical center in Canada | Prospective post-intervention study (150 patients) | Discharge home | None | Clinically significant unintentional discrepancies
Schnipper, 2009^25^ | Medical wards in two U.S. academic medical centers | RCT (162 patients, 7 medical teams) | Admission to hospital; discharge home | None | Clinically significant unintentional discrepancies Emergency department visits and hospitalizations within 30 days of discharge
Dedhia, 2009^26^ | Medical wards in U.S. academic medical center, community teaching hospital, and urban community hospital | Prospective before-after study (185 patients) | Discharge home | Safe STEPS intervention including admission assessment, communication with PCP, multidisciplinary discharge meeting | Emergency department visits and hospitalizations within 30 days of discharge
Jack, 2009^27^ | Medical ward in U.S. academic medical center | RCT (373 patients) | Discharge home | Nurse discharge advocates created after-hospital care plan, and post-discharge phone call | Emergency department visits and hospitalizations within 30 days of discharge
Koehler, 2009^28^ | Medical ward in U.S. academic medical center | RCT (21 patients, 2 hospital-medicine groups) | Admission to hospital, discharge home | Counseling by registered nurse | Emergency department visits and hospitalizations within 30 days of discharge
Koehler, 2009^28^ | Medical ward in U.S. academic medical center | RCT (20 patients, 2 hospital-medicine groups) | Admission to hospital, discharge home | Supplemental elderly care bundle: counseling by pharmacist, post-discharge phone call, discharge letter to PCP | Emergency department visits and hospitalizations within 30 days of discharge
Kramer, 2007^29^ | Medical ward in U.S. community teaching hospital | Prospective before-after study (136 patients) | Admission to hospital; discharge home | None | Emergency department visits and hospitalizations within 30 days of discharge
Schnipper, 2006^30^ | Medical ward in U.S. academic medical center | RCT (92 patients, 4 medical teams) | Discharge home | None | Emergency department visits and hospitalizations within 30 days of discharge
Showalter, 2011^31^ | All admitted patients through emergency department in U.S. academic medical center | Retrospective before-after study (17,516 patients) | Discharge home | Standardized mandatory electronic discharge instructions document with embedded computerized medication reconciliation | Emergency department visits and hospitalizations within 30 days of discharge
Walker, 2009^32^ | Medical ward in U.S. academic center | Prospective quasi-experimental study (358 patients, 2 medical teams and 1 hospitalist service) | Discharge home | Pharmacist-facilitated discharge program including counseling, provision of medication reconciliation list to PCP, and post-discharge phone call | Emergency department visits and hospitalizations within 30 days of discharge

Abbreviations: RCT, randomized control trial; PCP, primary care physician; Safe STEPS, Safe and Successful Transition of Elderly Patients Study.

It is notable that all but three interventions involved pharmacists playing a major role, which does not reflect routine practice, nor is it a requirement in the accreditation standard in either the U.S. or Canada. Some of the studies also involved additional enhancements beyond medication reconciliation itself (Table 2), such as the creation of a single place in the electronic medical record (EMR) to enter and update the preadmission medication history, or functionality in the EMR to facilitate creation of the pre-admission medication history. These characteristics probably also differentiate medication reconciliation as reported in the literature from routine practice.

Table 2, Chapter 25 Key features of the 12 included medication reconciliation interventions

Study | Intervention | Selection for More Complex Patients | Medication History | Electronic- or Paper-Based Medication Reconciliation | Institutional Informatics Functionality | Medication Reconciliation Became Order Process
Coffey, 2009^18^ | Medication reconciliation by pharmacy student | No | BPMH performed by pharmacy student | Paper^*^ | CPOE^*^ | No^*^
Cornish, 2005^2^ | Medication reconciliation by pharmacist, pharmacy student, or medical student | ≥ 4 medications | BPMH performed by pharmacist, pharmacy student, or medical student | Paper^*^ | Limited^*^ | No^*^
Gleason, 2004^19^ | Medication reconciliation by pharmacist | No | Structured history performed by pharmacist or PharmD student | Paper^*^ | Limited^*^ | No^*^
Gleason, 2010^20^ | Medication reconciliation by pharmacist | No | Structured history performed by pharmacist | Electronic^*^ | EMR, CPOE^*^ | No^*^
Kripalani, 2012^21^ | Medication reconciliation by physician and nurse | No | History performed by pharmacist | Electronic (at one site) | EMR, CPOE, Preadmission Medication List Builder (embedded at one site) | Yes (at one site)
Kripalani, 2012^21^ | Medication reconciliation by pharmacist with pharmacist intervention | No | History performed by pharmacist | Electronic (at one site) | EMR, CPOE, Preadmission Medication List Builder (embedded at one site) | Yes (at one site)
Lee, 2010^5^ | Medication reconciliation by pharmacist | No | BPMH performed by pharmacist | Both^*^ | EMR, CPOE (partial)^*^ | Not reported
Pippins, 2008^22^ | Medication reconciliation by pharmacist | No | BPMH performed by pharmacist | Not reported | Not reported | Not reported
Stone, 2010^23^ | Medication reconciliation by pharmacist | Identification of medically complex conditions based on published guidelines | BPMH performed by pharmacist | Paper^*^ | EMR^*^ | No^*^
Vira, 2006^24^ | Medication reconciliation by pharmacist | No | BPMH performed by pharmacist | Paper^*^ | Limited^*^ | No^*^
Wong, 2008^4^ | Medication reconciliation by pharmacist or pharmacy resident | No | BPMH performed by pharmacist | Paper^*^ | EMR, CPOE^*^ | No^*^
Schnipper, 2009^25^ | Medication reconciliation by physician and confirmed by pharmacist or nurse | No | BPMH performed by physician and verified by nurse and pharmacist | Electronic^*^ | EMR, CPOE, linkage to Preadmission Medication List Builder^*^ | Partial (not at time of study)^*^
Dedhia, 2009^26^ | Medication reconciliation by physician and reviewed by pharmacist | Age ≥ 65 | History performed by physician and reviewed by pharmacist | Paper^*^ | EMR, CPOE^*^ | No^*^
Jack, 2009^27^ | Medication reconciliation by nurse | None | Not reported | Electronic^*^ | EMR, CPOE^*^ | No^*^
Koehler, 2009^28^ | Medication reconciliation by nurse and reviewed by pharmacist | Age ≥ 70, ≥ 5 medications, ≥ 3 chronic comorbid conditions, requirement for assistance with ≥ 1 ADL | Not reported | Paper^*^ | Limited^*^ | No^*^
Koehler, 2009^28^ | Medication reconciliation by pharmacist with supplementary elderly care bundle | Age ≥ 70, ≥ 5 medications, ≥ 3 chronic comorbid conditions, requirement for assistance with ≥ 1 ADL | Not reported | Paper^*^ | Limited^*^ | No^*^
Kramer, 2007^29^ | Medication reconciliation by pharmacist and physician | One or more of: ≥ 7 medications, significant comorbid condition, previous admission for ADR, ≥ 4 drug allergies | Structured history performed by pharmacist | Electronic^*^ | Limited (pharmacist electronic order entry)^*^ | Yes^*^
Schnipper, 2006^30^ | Medication reconciliation by pharmacist | None | History performed by pharmacist | Paper^*^ | EMR, CPOE^*^ | No^*^
Showalter, 2011^31^ | Medication reconciliation by physician | None | Not reported | Electronic^*^ | EMR, CPOE, electronic discharge program (embedded as force function)^*^ | Not reported
Walker, 2009^32^ | Medication reconciliation by pharmacist | One or more of: ≥ 5 medications, ≥ 1 targeted medications^**^, medication requiring monitoring, ≥ 2 changes to regimen, dementia or confusion, or inability to manage medications | History performed by pharmacist | Electronic^*^ | EMR, CPOE, internal electronic pharmacy database^*^ | No^*^

Abbreviations: BPMH, best possible medication history; CPOE, computerized physician order entry; EMR, electronic medical record; ADL, activity of daily living; ADR, adverse drug reaction

* Information obtained by communication with authors.

** Targeted medications included digoxin, diuretics, anticoagulants, sedatives, opioids, asthma and/or chronic obstructive pulmonary disease medications, angiotensin converting enzyme inhibitor and/or angiotensin receptor blocker.

### Clinically Significant Unintended Medication Discrepancies

Studies varied in their definitions of clinical importance and categories of severity applied to each medication discrepancy. However, all included studies reported a category that amounted to “trivial,” “minor,” or “unlikely to cause harm,” with all other unintentional discrepancies deemed to be “clinically significant.” This definition corresponds to the term, potential adverse drug events (ADEs), though only three included studies explicitly used this term.21,25 We required that assessments of clinical severity be performed by at least one clinician independent from the medication reconciliation process. We also required an explicit statement that unintentional discrepancies were distinguished from intentional medication changes, as well as a clear description of the method for doing so.

As shown in Figure 2, rates for clinically significant discrepancies ranged from a low of 0.11 per patient to a high of 1.43. The only randomized controlled trial of medication reconciliation vs. usual care yielded an estimate of 0.27 per patient, but this result included potential ADEs, not just unintended discrepancies. This study is discussed in more detail below.

Figure 2, Chapter 25 Median and interquartile range for the number of clinically significant unintentional discrepancies per patient for the 13 included interventions

Figure 2 illustrates the 13 medication reconciliation interventions giving the median and interquartile range for the number of clinically significant unintentional discrepancies per patient. The results of the figure are further explained in the text above and below figure 2.

Across 13 medication reconciliation interventions, the median value for the number of clinically significant unintentional discrepancies per patient was 0.35 (interquartile range [IQR] 0.25-0.88). Four interventions (2 from the same study21) reported notably higher values (Figure 2). No features of the intervention (Table 2), such as selection for high risk patients, inclusion of additional interventions beyond medication reconciliation, or integration with clinical informatics applications explained these outlying results.

Only a minority of unintended discrepancies had clinical significance. The meta-analytic mean for the proportion of unintended discrepancies that were clinically significant was 35.1% (95% CI: 27.5%-43.6%). This result exhibited significant heterogeneity (I^2^ =92%) as the results ranged from 15% to 54% (median: 34%, IQR 28%-49%). The meta-analytic average for the proportion of patients with at least one clinically significant unintended discrepancy was 39.3% (95% CI: 21.4%-60.5%). This result also exhibited significant heterogeneity (I^2^= 95%), due to a wide range in values, from 15% to 60% (median 45%, IQR 31%-56%).

Only two randomized controlled trials25,30 evaluated the impact of medication reconciliation in comparison with usual care using the established concept of adverse drug event (ADE). One trial30 involved randomizing 178 patients being discharged from the medical service at a teaching hospital in Boston to an intervention that included medication reconciliation and counseling by a pharmacist, as well as a follow-up phone call within 5 days. For patients in the control arm, nurses provided discharge counseling and pharmacists reviewed medication orders, but did not perform a formal reconciliation process. Significantly fewer patients in the intervention arm experienced preventable ADEs (1% vs. 11%; p=0.01), though total ADEs did not differ between the two groups.

A subsequent, cluster randomized trial from the same research group involved 14 medical teams at two teaching hospitals in Boston.25 The intervention included a web-based application using the hospital's electronic medical record (which included ambulatory visits) to create a preadmission medication list in order to facilitate the medication reconciliation process. Of note, the intervention's effect achieved statistical significance at one of the hospitals, with a relative reduction of potential ADEs (equivalent to clinically significant unintended medication discrepancies) of 0.72 (95% CI, 0.52-0.99), but not at the other (0.87, 95% CI, 0.57-1.32). The authors attributed this difference to variation in the degree to which the two hospitals integrated the medication reconciliation tool into the computerized order entry applications at discharge.

### Emergency Department Visits and Readmission Within 30 Days

Across nine medication reconciliation interventions, the median proportion of patients with emergency department visits or hospitalizations within 30 days of discharge was 28% (IQR, 20%-32%). The median rate of hospitalization or emergency department visits across seven studies with control data was 30% (IQR, 22%-31%), a difference that was not statistically significant.

Across three randomized controlled trials, readmissions and emergency department visits were significantly reduced by 23% (95% CI, 5%-37%; I^2^ 24%) (Figure 3). However, this pooled result was driven by the statistically significant reduction achieved by an intensive intervention33 that included several interventions beyond medication reconciliation that were specifically aimed at reducing readmissions.

Figure 3, Chapter 25 Emergency department visits and hospitalizations within 30 days of discharge in three randomized controlled trials

Figure 3 is an image depicting the statistics for each of the three randomized controlled trials including risk ratio, lower limit, upper limit and additional interventions. Further it includes the risk ratio and 95% CI for each of the three studies. The figure is described above in the text above and below figure 3.

With respect to the appropriate time period for observing an impact on post-discharge utilization, it is particularly noteworthy that the two randomized controlled trials25,30 that included no additional interventions beyond medication reconciliation did not reduce hospital utilization within 30 days. However, one additional randomized controlled trial34 met all of our inclusion criteria but was excluded because it measured hospital utilization at 12 months, rather than 30 days, following discharge. This trial reported a statistically significant 16% reduction in all visits to the hospital. The intervention consisted of intensive medication reconciliation in which pharmacists identified drug related problems beyond unintended discrepancies, delivered counseling to patients at admission and discharge, and telephoned patients 2 months after discharge to ensure adequate home management of medications.

The lack of impact of medication reconciliation by itself on hospitalization utilization within 30 days of discharge may reflect the need to consider a longer window of observation to demonstrate benefits from resolving unintended medication discrepancies. For instance, inadvertent discontinuation of cholesterol lowering medications, antiplatelet or anticoagulant agents, thyroid hormone replacement, anti-resorptive therapy for osteoporosis, and gastric acid suppression agents all may produce adverse clinical effects requiring hospital utilization in the long term, but not necessarily within 30 days of discharge.

#### Limitations of the Evidence

As emphasized at the outset, all but three of the 20 interventions that include any assessment of the impacts of medication reconciliation involved clinical pharmacists as a key part of the intervention. Thus, the literature provides evidence only for medication reconciliation supported by pharmacists, which is not the intervention implemented in routine practice and required by accreditation bodies in the U.S. and Canada.

In two RCTs that evaluated medication reconciliation using ADEs as the outcome, one30 reported a reduction in preventable ADEs, but the other21 (a comparably rigorous RCT from the same research group) found only a reduction in potential ADEs at one of the two sites. The remaining included studies evaluated the outcomes that have been judgments about the potential clinical importance of detected medication discrepancies. These judgments are far from straightforward. First, there is the usual problem with inter-rater reliability seen in studies of adverse events and ADEs. Second, assessing the impact of unintended medication discrepancies involves speculation about a number of factors, including not just the potential risk to a given patient associated with the discrepancy, but also the likelihood that the discrepancy will persist and for how long before it is eventually detected by the patient, an outpatient physician, or some later health care encounter.

In the studies that reported particularly serious (e.g., potentially life-threatening) discrepancies, few events were judged to be serious. Moreover, in the widely quoted study of post-discharge adverse events,35 even though one of the examples of post-discharge adverse events involved a medication discrepancy, the subsequent analysis of ADEs highlighted problems with drug monitoring as the most common cause, not problems with medication reconciliation.36

## What Are the Harms of the Patient Safety Practice?

Mistakes in the medication reconciliation process have the potential to become “hardwired” into the patient record. Once medication reconciliation has occurred, personnel caring for a given patient may rely exclusively on the documented medication history and be less likely to confirm the accuracy with the patient or other sources.

The larger issue with medication reconciliation concerns the opportunity costs. Clinical pharmacists have proven roles in the prevention of adverse drug events,37-39 but they are in short supply in most hospitals. Thus, involving pharmacists in medication reconciliation, the method for which all the evidence of efficacy exists, risks taking these personnel away from other important activities related to patient safety.

## How Has the Patient Safety Practive Been Implemented, and in What Context?

The number and intensity of medication reconciliation activities in the literature varies substantially. Table 3 outlines a continuum of varying levels of medication reconciliation intensity ranging from “Bronze” (simply a “best possible medical history” and admission reconciliation) to “Silver, Gold, Platinum and Diamond.” The more advanced levels of medication reconciliation involve progressions in interprofessional collaboration and patient participation, integration of reconciled information into discharge summaries and prescriptions, as well as the delivery of more comprehensive medication education and counseling to patients.

Table 3, Chapter 25 Medication reconciliation in varying levels of intensity as seen in published studies

Level | Key Components | Published Examples
“Bronze” | BPMH with admission reconciliation | Cornish et al. 2005^2^; Kwan et al. 2007^3^
“Silver” | Bronze + reconciliation at discharge by prescribing physician | Schnipper et al. 2009^25^; Wong et al. 2008^4^
“Gold” | Silver + discharge reconciliation is interprofessional (e.g., prescribing physician and pharmacist) + Electronically generated discharge prescription | Cesta et al. 2006^40^; Dedhia et al. 2009^26^; Schnipper et al. 2009^25^
“Platinum” | Gold + attention to broader medication issues, such as appropriateness of medication choices (e.g., safe prescribing in the elderly) | Dedhia et al. 2009^26^; Murphy et al. 2009^41^; Nazareth et al. 2001^42^; Al-Rashed et al. 2002^43^
“Diamond” | Platinum + additional elements, such as; - pharmacist-led medication counseling prior to discharge (including discussion of medication changes); - communicating medication changes directly to community pharmacy; - post-discharge follow-up phone call to patient by hospital clinician (e.g., nurse or pharmacist) | Gillespie et al. 2009^34^; Jack et al 2009^27^; Karapinar-Çarkit et al. 2009^44^; Schnipper et al. 2006^30^; Walker et al. 2009)32

## Are There Any Data About the Effect of Context On Effectiveness?

We did not identify any studies that explicitly assessed the differential effect of various contexts on the effectiveness of medication reconciliation. However, we note that our review is limited to interventions within hospitals, so that effectiveness in the outpatient setting is not assessed, and further that the intervention needed to include a clinical pharmacist. Hence, to the extent that “context matters”, these interventions have only been assessed in academically-affiliated hospitals using clinical pharmacists, and effectiveness in other contexts is not established.

## Are There Any Data About Costs?

Some studies provided informal data on costs, loosely estimating the amount of time spent by pharmacists performing medication reconciliation and equating that to a dollar value.19 One model-based study45 considered the cost effectiveness of five pharmacist-led strategies for reducing adverse drug events. In this analysis, pharmacist-led medication reconciliation carried a reasonable probability of cost effectiveness (compared with no reconciliation) at £10,000 ($16,272) per quality adjusted life year. The main limitation of this analysis is the uncertainty surrounding assumptions about reductions in actual ADEs from reducing potential ADEs.

## Conclusions and Comment

Medication reconciliation addresses the conceptually plausible and well-documented problem of unintended medication discrepancies introduced at the time of transitions in care. The frequency of non-trivial discrepancies varies across studies—those studies that characterized extremely severe discrepancies reported few such events. One well-designed randomized controlled trial reported a significant reduction in potential ADEs at one of the two study hospitals. The only study that reported a reduction on preventable ADEs (within 30 days of discharge) found no difference in total ADEs. By itself, medication reconciliation probably does not reduce hospital utilization within 30-days of discharge, but may do so when bundled with other interventions aimed at improving transitions in care. It may by itself reduce hospital utilization over timelines longer than 30 days.

Given limited resources, the paramount issue becomes how to target medication reconciliation in order to direct resources most efficiently. This is especially important given that all but three of the included interventions involved the use of pharmacists to conduct medication reconciliation. Disappointingly, the studies that selected high-risk patients did not consistently report higher rates of clinically significant unintentional discrepancies or show larger effects on readmissions.

This null result could reflect the limited number of studies. But, the high risk criteria used also have plausible limitations. For instance, elderly patients and patients with multiple chronic conditions may take large numbers of medications. However, their medication regimens may remain stable for some time and/or are well known to the patient or their caregivers. These risk factors for unintended medication discrepancies do not account for such nuances. A more direct risk factor is probably frequent or recent changes to medication regimens. Unfortunately, this risk factor cannot be ascertained reliably without conducting a thorough medication history, not unlike the BPMH required for medication reconciliation. A summary table is located below (Table 4).

Table 4, Chapter 25 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues How Much do We Know?/How Hard Is it?
Common/Low | Moderate | Low | Moderate | Moderate/Moderate

## References

1 Tam VC, Knowles SR, Cornish PL, et al. Frequency, type and clinical importance of medication history errors at admission to hospital: a systematic review. CMAJ. Aug. 30. 2005;173(5):510-5. [pmid: 16129874].
2 Cornish PL, Knowles SR, Marchesano R, et al. Unintended medication discrepancies at the time of hospital admission. Arch Intern Med. Feb. 28. 2005;165(4):424-9. [pmid: 15738372].
3 Kwan Y, Fernandes OA, Nagge JJ, et al. Pharmacist medication assessments in a surgical preadmission clinic. Arch Intern Med. May. 28. 2007;167(10):1034-40. [pmid: 17533206].
4 Wong JD, Bajcar JM, Wong GG, et al. Medication reconciliation at hospital discharge: evaluating discrepancies. Ann Pharmacother. Oct. 2008;42(10):1373-9. [pmid: 18780806].
5 Lee JY, Leblanc K, Fernandes OA, et al. Medication reconciliation during internal hospital transfer and impact of computerized prescriber order entry. Ann Pharmacother. Dec. 2010;44(12):1887-95. [pmid: 21098753].
6 Bell CM, Brener SS, Gunraj N, et al. Association of ICU or hospital admission with unintentional discontinuation of medications for chronic diseases. JAMA. Aug. 24. 2011;306(8):840-7. [pmid: 21862745].
7 Satterthwaite PS, Atkinson CJ. Using ‘reverse triage’ to create hospital surge capacity: Royal Darwin Hospital's response to the Ashmore Reef disaster. Emerg Med J. 2010. Oct. 28. [pmid: 21030549].
8 Hospital: 2012 National Patient Safety Goals. The Joint Comision. www.jointcommission.org/hap_2012_npsgs/. Jan 8, 2012.
9 Institute for Safe Medication Practices Canada. Medication Reconciliation. 2011. Retrieved Jan 8, 2012. www.ismp-canada.org/medrec/.
10 Bayoumi I, Howard M, Holbrook AM, et al. Interventions to improve medication reconciliation in primary care. Ann Pharmacother. Oct. 2009;43(10):1667-75. [pmid: 19737997].
11 Weingart SN, Cleary A, Seger A, et al. Medication reconciliation in ambulatory oncology. Joint Commission journal on quality and patient safety / Joint Commission Resources. Dec. 2007;33(12):750-7. [pmid: 18200900].
12 Mueller SK, Sponsler KC, Kripalani S, et al. Hospital-based medication reconciliation practices: a systematic review. Arch Intern Med. Jul. 23. 2012;172(14):1057-69. [pmid: 22733210].
13 Midlov P, Bahrani L, Seyfali M, et al. The effect of medication reconciliation in elderly patients at hospital discharge. Int J Clin Pharm. Feb. 2012;34(1):113-9. [pmid: 22207271].
14 Abdel-Qader DH, Harper L, Cantrill JA, et al. Pharmacists' interventions in prescribing errors at hospital discharge: an observational study in the context of an electronic prescribing system in a UK teaching hospital. Drug Saf. Nov. 1. 2010;33(11):1027-44. [pmid: 20925440].
15 Steurbaut S, Leemans L, Leysen T, et al. Medication history reconciliation by clinical pharmacists in elderly inpatients admitted from home or a nursing home. Ann Pharmacother. Oct. 2010;44(10):1596-603. [pmid: 20736427].
16 Norris CM, Thomas V, Calvert PS. An audit to evaluate the acceptability of a pharmacist electronically prescribing discharge medication and providing information to GPs. Pharmaceutical Journal. 2001;276(Dec):857-9.
17 Climente-Marti M, Garcia-Manon ER, Artero-Mora A, et al. Potential risk of medication discrepancies and reconciliation errors at admission and discharge from an inpatient medical service. Ann Pharmacother. Nov. 2010;44(11):1747-54. [pmid: 20923946].
18 Coffey M, Mack L, Streitenberger K, et al. Prevalence and clinical significance of medication discrepancies at pediatric hospital admission. Acad Pediatr. Sep-Oct. 2009;9(5):360-5 e1. [pmid: 19640822].
19 Gleason KM, Groszek JM, Sullivan C, et al. Reconciliation of discrepancies in medication histories and admission orders of newly hospitalized patients. Am J Health Syst Pharm. Aug. 15. 2004;61(16):1689-95. [pmid: 15540481].
20 Gleason KM, McDaniel MR, Feinglass J, et al. Results of the Medications at Transitions and Clinical Handoffs (MATCH) study: an analysis of medication reconciliation errors and risk factors at hospital admission. J Gen Intern Med. May. 2010;25(5):441-7. [pmid: 20180158].
21 Kripalani S, Roumie CL, Dalal AK, et al. Effect of a Pharmacist Intervention on Clinically Important Medication Errors After Hospital Discharge: A Randomized Trial. Ann Intern Med. Jul. 3. 2012;157(1):1-10. [pmid: 22751755].
22 Pippins JR, Gandhi TK, Hamann C, et al. Classifying and predicting errors of inpatient medication reconciliation. J Gen Intern Med. Sep. 2008;23(9):1414-22. [pmid: 18563493].
23 Stone BL, Boehme S, Mundorff MB, et al. Hospital admission medication reconciliation in medically complex children: an observational study. Arch Dis Child. Apr. 2010;95(4):250-5. [pmid: 19948664].
24 Vira T, Colquhoun M, Etchells E. Reconcilable differences: correcting medication errors at hospital admission and discharge. Qual Saf Health Care. Apr. 2006;15(2):122-6. [pmid: 16585113].
25 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. Apr. 27. 2009;169(8):771-80. [pmid: 19398689].
26 Dedhia P, Kravet S, Bulger J, et al. A quality improvement intervention to facilitate the transition of older adults from three hospitals back to their homes. J Am Geriatr Soc. Sep. 2009;57(9):1540-6. [pmid: 19694865].
27 Jack BW, Chetty VK, Anthony D, et al. A reengineered hospital discharge program to decrease rehospitalization: a randomized trial. Annals of internal medicine. Feb. 3. 2009;150(3):178-87. [pmid: 19189907].
28 Koehler BE, Richter KM, Youngblood L, et al. Reduction of 30-day postdischarge hospital readmission or emergency department (ED) visit rates in high-risk elderly medical patients through delivery of a targeted care bundle. J Hosp Med. Apr. 2009;4(4):211-8. [pmid: 19388074].
29 Kramer JS, Hopkins PJ, Rosendale JC, et al. Implementation of an electronic system for medication reconciliation. Am J Health Syst Pharm. Feb. 15. 2007;64(4):404-22. [pmid: 17299180].
30 Schnipper JL, Kirwin JL, Cotugno MC, et al. Role of pharmacist counseling in preventing adverse drug events after hospitalization. Arch Intern Med. Mar. 13. 2006;166(5):565-71. [pmid: 16534045].
31 Showalter JW, Rafferty CM, Swallow NA, et al. Effect of standardized electronic discharge instructions on post-discharge hospital utilization. J Gen Intern Med. Jul. 2011;26(7):718-23. [pmid: 21499825].
32 Walker PC, Bernstein SJ, Jones JN, et al. Impact of a pharmacist-facilitated hospital discharge program: a quasi-experimental study. Arch Intern Med. Nov. 23. 2009;169(21):2003-10. [pmid: 19933963].
33 Jack BW, Chetty VK, Anthony D, et al. A reengineered hospital discharge program to decrease rehospitalization: a randomized trial. Ann Intern Med. Feb. 3. 2009;150(3):178-87. [pmid: 19189907].
34 Gillespie U, Alassaad A, Henrohn D, et al. A comprehensive pharmacist intervention to reduce morbidity in patients 80 years or older: a randomized controlled trial. Arch Intern Med. May. 11. 2009;169(9):894-900. [pmid: 19433702].
35 Forster AJ, Murff HJ, Peterson JF, et al. The incidence and severity of adverse events affecting patients after discharge from the hospital. Annals of internal medicine. Feb. 4. 2003;138(3):161-7. [pmid: 12558354].
36 Forster AJ, Murff HJ, Peterson JF, et al. Adverse drug events occurring following hospital discharge. J Gen Intern Med. Apr. 2005;20(4):317-23. [pmid: 15857487].
37 Kaboli PJ, Hoth AB, McClimon BJ, et al. Clinical pharmacists and inpatient medical care: a systematic review. Arch Intern Med. May. 8. 2006;166(9):955-64. [pmid: 16682568].
38 Kucukarslan SN, Peters M, Mlynarek M, et al. Pharmacists on rounding teams reduce preventable adverse drug events in hospital general medicine units. Arch Intern Med. Sep. 22. 2003;163(17):2014-8. [pmid: 14504113].
39 Lee AJ, Boro MS, Knapp KK, et al. Clinical and economic outcomes of pharmacist recommendations in a Veterans Affairs medical center. Am J Health Syst Pharm. Nov. 1. 2002;59(21):2070-7. [pmid: 12434719].
40 Cesta A, Bajcar JM, Ong SW, et al. The EMITT study: development and evaluation of a medication information transfer tool. Ann Pharmacother. Jun. 2006;40(6):1074-81. [pmid: 16735652].
41 Murphy EM, Oxencis CJ, Klauck JA, et al. Medication reconciliation at an academic medical center: implementation of a comprehensive program from admission to discharge. Am J Health Syst Pharm. Dec. 1. 2009;66(23):2126-31. [pmid: 19923314].
42 Nazareth I, Burton A, Shulman S, et al. A pharmacy discharge plan for hospitalized elderly patients--a randomized controlled trial. Age and ageing. Jan. 2001;30(1):33-40. [pmid: 11322670].
43 Al-Rashed SA, Wright DJ, Roebuck N, et al. The value of inpatient pharmaceutical counselling to elderly patients prior to discharge. Br J Clin Pharmacol. Dec. 2002;54(6):657-64. [pmid: 12492615].
44 Karapinar-Carkit F, Borgsteede SD, Zoer J, et al. Effect of medication reconciliation with and without patient counseling on the number of pharmaceutical interventions among patients discharged from the hospital. Ann Pharmacother. Jun. 2009;43(6):1001-10. [pmid: 19491320].
45 Karnon J, Campbell F, Czoski-Murray C. Model-based cost-effectiveness analysis of interventions aimed at preventing medication error at hospital admission (medicines reconciliation). J Eval Clin Pract. Apr. 2009;15(2):299-306. [pmid: 19335488].