# Inpatient Intensive Glucose Control Strategies To Reduce Death and Infection (NEW)

## How Important Is the Problem?

Hyperglycemia is a common finding among medical and surgical inpatients with and without known diabetes.1,2 Moreover, several observational studies have found an association between inpatient hyperglycemia and poor outcomes in patients undergoing general and cardiac surgery,3,4 and in patients with a variety of conditions including myocardial infarction, stroke, and trauma.5-7 Hyperglycemia could contribute to these poor health outcomes by causing inflammation, oxidative stress, poor immune function, endothelial dysfunction, and tissue ischemia.8 Given the mechanistic and observed association between hyperglycemia and poor outcomes in hospitalized patients, significant interest has developed in using intensive insulin therapy (IIT) to control blood glucose in a variety of inpatient subpopulations. However, over-aggressive use of insulin can result in dangerously low levels of blood glucose, which also can be harmful to patients. This chapter reports the results of a systematic review conducted in 2010-2011 on the use of IIT to control blood glucose among inpatients as well as the findings of studies released subsequent to the searches we conducted for that review.

## What Is the Patient Safety Practice?

The evidence evaluating the balance of benefits and harms from the use of IIT to control blood glucose in hospitalized patients is detailed in the following sections. Overall, trials have not consistently found that use of IIT to lower blood glucose to normal levels (i.e., 80-110 mg/dL) improves health outcomes, whereas aggressive IIT approaches are clearly associated with high rates of hypoglycemia. Nevertheless, many organizations continue to recommend moderate blood glucose control (e.g., 140–200 mg/dL) because of the association of high blood glucose with infection, poor wound healing, dehydration, and other complications. Given the uncertainty about the benefits of IIT, the remaining concerns that untreated hyperglycemia is harmful, and the hypoglycemia risks associated with IIT, the patient safety practice of interest is the implementation of inpatient glycemic control strategies that minimize the risk of hypoglycemia.

## What Are the Beneficial Effects of the Patient Safety Practice?

Initially encouraging trial data in critically ill patients spurred some organizations to recommend tight glycemic control strategies be implemented in hospitals across a variety of settings.8,9 In one of the key trials fueling these recommendations, 1,548 patients in a single surgical intensive care unit (SICU) were randomized to either an intensive insulin regimen, with a goal glucose range of 80-110 mg/dl, or a conventional insulin regimen with a goal glucose range of 180-200 mg/dl.10 The trial was terminated early after finding all-cause ICU mortality was significantly lower in the IIT group (4.6% vs. 8%, relative risk [RR] 0.58, 95% CI, 0.38 to 0.78) (Table 1). The short-term mortality benefit was limited to the subgroup of patients who required 5 or more days of ICU care (10.6% vs. 20.2%, p = 0.005); long-term mortality did not differ between the two groups.11

Table 1, Chapter 22 Large trials (n > 500) evaluating the health outcome effects of intensive insulin therapy

Patient Population; Diabetes Mellitus (%); Single or Multicenter; Country; Study Quality | Implementation Context | Glucose Target, T v C (mg/dL) | Inpatient BG Achieved, T v C (mg/dL) | Mortality T v C (RR, 95% CI) | Hypoglycemia Definition (mg/dL), rate ,T v C, RR (95%CI) | Other Reported Outcomes^*^ T v C
SICU 13 Single center Belgium10 Fair | Insulin protocol was developed and use overseen by study investigators. | 80-110 v 180-200 | 103 v 153^†^ (p<0.001) | ICU mortality 4.6 v 8% (p=0.005 unadjusted) RR 0.42 (95% CI 0.22-0.62); Hospital mortality: 7.2 v 10.9% (p=0.01) RR 0.66; 95% CI 0.48-0.92 | <40, 5 v 0.76%, RR 6.65 (2.83-15.62) | Renal replacement 4.8 v 8.2% (p=0.007) Sepsis 4.2 v 7.8% (p=0.0003)
Neurosurgical ICU NR Single center Italy58 Fair | Efforts made to limit nursing turnover. New nursing staff worked with experienced staff. | 80-110 v 180-200 | 92 v 143^‡^ (p<0.001) | 6-month mortality: 74.0 v 72.0% (p=0.82) | <50, 93.8 v 62.8%, p<0.001 | Sepsis 2.9 v 3.3% (p=NS) Long-term disability: 40.2 v 41.1% (p=0.98)
MICU 16 Single center Belgium59 Fair | Study conducted in a hospital that had already conducted similar IIT study in SICU patients. Authors note the nurse:bed ratio of 2.5 was not changed for study. | 80-110 v 180-200 | 111 v 153^†^ (p<0.001) | ICU mortality: 24.2 v 26.8% (p=0.31) Hospital mortality: 37.3 v 40.0% (p=0.33) RR 0.93; 95% CI 0.81-1.08 90d mortality: 35.9 v 37.7% (p=0.53) | <40, 18.7 v 3.1% | Infection 0.7 vs 0.8% (p=NS) Renal replacement 20.8 v 22.7% (p=0.50)
MICU 30 Multicenter Germany21 Fair | No details provided | 80-110 v 180-200 | 112 v 151^†^ (p<0.001) | 28d mortality: 24.7 v 26% (p=0.74) RR 0.95, 95% CI 0.70-1.28 90d mortality: 39.7 v 35.4% (p=0.31) | <40, 17 v 4.1% RR 4.11 (95% CI 2.21-7.63) | Renal replacement 27.5 v 22.5% (p=0.001)
MICU/SICU 17 T, 22 C (p=0.031) Multicenter Europe60 Fair | Characteristics from each study site were reported. Median nurse:bed ratio was 2. ICUs ranged widely in size, patient volume, and number of glucometers per ICU. | 80-110 v 140-180 | 117 v 144^‡^ (p<0.001) | ICU mortality: 17.2 v 15.3% (p=0.41) Hospital mortality: 23.3 v 19.4% (p=0.11) 28d mortality: 18.7 v 15.3% (p=0.14) | < 40, 8.7 v 2.7% | Renal replacement (patient days) 519 v 523 (p=0.75)
MICU/SICU 32 T, 48 C (p<0.001) Single center Saudi Arabia19 Fair | 24/7 ICU coverage by intensivists. Protocol designed by multidisciplinary team at study site. Physicians and nurses attended training sessions before and during study. | 80-110 v 180-200 | 115 v 171^‡^ (p<0.001) | ICU mortality: 13.5 v 17.1% (p=0.70) RR‖ 1.09 (0.70-1.72) Hospital mortality: 27.1 v 32.3% (p=0.19) RR‖ 0.84 (0.64-1.09) | < 40, 28.6 v 3.1%, p < 0.001 | Renal replacement 11.7 v 12.1% (p=0.89)‖ Sepsis 36.9 v 40.9% (p=0.35)
MICU/SICU 13 T, 12 C (p=NS) Single center Colombia54 Fair | Three month staff training period before study. | 80-110 v 180-200 | 120 v 149^‡^ (p,0.001) | ICU mortality: 33.1 v 31.2%; RR 1.06 (0.82-1.37) 28d mortality: 36.6 v 32.4%; RR 1.1 (0.85-1.42) | <40, 8.3 v 0.8% | Infection 27.2 v 33.2% (p=NS) Renal replacement 10.8 v 13% (p=0.45)
MICU/SICU 20 Multicenter International13 Fair | Pre-trial pilot studies carried out to test/improve insulin protocol. Final computerized insulin protocol algorithm accessible to study sites through a central Web site. No clear explicit training prior to study. | 80-108 v <180 | 115 v 144§ (p<0.001) | 28d mortality: 22.3 v 20.8% (p=0.17) RR 1.07 (0.97-1.18) 90d mortality: 27.5 v 24.9% (p=0.02) RR 1.14 (1.02-1.28) | <40, 6.8 v 0.5% OR 14.7 (9.0-25.9) | Renal replacement 15.4 v 14.5% (p=0.34) Sepsis 12.8 v 12.4% (p=0.57)
Acute MI 39 Multicenter CCU Sweden61 Fair | No details provided | 126-198 v NR | 24 hours: T: 172.8 (59.4) C: 210.6 (73.8) p < .001 | 3 month mortality: 12.4% v 15.6%, p = NS 1 year mortality: 18.6% v 26.1 %, RR 0.69; 95% CI 0.49-0.96 | <54, 15.0 v 0% (p < .001)
Acute MI 77 established DM; 23 new DM of < 1y Multicenter Europe62 Poor | No details provided | group 1 and 2: 126-180 group 3: NR | 24 hours: group 1: 163.8 (54.0), group 2: 163.8 (50.4), group 3: 180.0 (64.8) p = .0001 | Adjusted 2-year mortality: Group 1 v 3 = 1.19 (0.86 - 1.64) Group 2 v 3 = 1.23 (0.89 - 1.69) | < 54, Gr 1 v Gr2 v Gr3: 12.7 v 9.6 v 1.0
Stroke 17 Mutlicenter Britain63 Poor | Conducted as a “pragmatic” trial as part of routine clinical care. No clear explicit training prior to study. | 72-126 v <306 | 24 hour mean difference I v C (95% CI): 10.3 (4.9 - 15.5), p < .0001^†^ | 90-day mortality: 30.0% v 27.3%, OR (95% CI) = 1.14 (0.86-1.51) 90-day severe disability: 35.1% v 36.0%, OR (95% CI) = 0.96 (0.70-1.32) | < 72 for > 30 mins, 15.7, control group rate NR

Notes: Abbreviations: BG = Blood glucose; d = day; CCU = coronary care unit ; ICU = intensive care unit; MICU = medical intensive care unit; SICU = surgical intensive care unit; C = comparator; DM = diabetes mellitus; NR = not reported; NS = not statistically significant; RR = relative risk; T = treatment

Other reported outcomes include renal replacement, infection, cardiovascular events, and long-term disability.

Quality was assessed using criteria from the U.S. Preventive Services Task Force.

SI unit conversion for glucose: 1 mg/dL × 0.0555 = 1 mmol/L.

* Infection includes wound infection, urinary tract infection, or pneumonia; or a combination of these.

† Morning blood glucose.

‡ Average of blood glucose measurements, not otherwise specified.

However, over the last decade, IIT trials have failed to replicate these results consistently. Our recent meta-analysis of 21 randomized controlled trials (RCTs), including a total of 14,768 inpatients, found no effect of IIT on short-term mortality (RR 1.00, 95% CI 0.94 to 1.07) (see Figure 1), with remarkably little heterogeneity among studies (I^2^ = 0.0%, p=0.463).12 The body of evidence is strongest in ICU settings.

Figure 1, Chapter 22 Short-term mortality in studies of intensive insulin therapy, by inpatient setting and condition

Figure taken from Kansagara et al., 2011^12^

Kansagara D, Fu R, Freeman M, Wolf F, Helfand M. Intensive insulin therapy in hospitalized patients: a systematic review. Ann Intern Med. Feb 15 2011; 154. Permission granted from the American College of Physicians (Annals of Internal Medicine is the original source of the material).

Figure 1 is a forest plot of studies reporting the relative risk ratio for short-term mortality with the use of intensive insulin therapy (IIT) by inpatient setting and condition. The figure illustrates the authors' point that, “Over the last decade, IIT trials have failed to replicate these results consistently. Our recent meta-analysis of 21 randomized controlled trials (RCTs), including a total of 14,768 inpatients, found no effect of IIT on short-term mortality (RR 1.00, 95% CI 0.94 to 1.07)…with remarkably little heterogeneity among studies (I2 = 0.0%, p=0.463). The body of evidence is strongest in ICU settings.” This figure is taken, with permission, from the 2011 article by Kansagara and colleagues published in Annals of Internal Medicine.

Table 2 summarizes the main characteristics and results from the largest trials (n > 500 patients). The NICE-SUGAR trial, with 6,104 medical intensive care unit (MICU) and SICU patients, was by far the largest and likely provides the most generalizable results, given its size, multicenter design, and the broad ICU population included.13 Patients randomized to a lower blood glucose target (80-110 mg/dL) had higher 90-day mortality than those assigned a higher blood glucose target (140-180 mg/dL), with approximately one excess death for every 39 patients treated with the more intensive protocol (n = 6,022 with 90-day outcomes reported; RR 1.14; 95% CI 1.02 to 1.28).

Table 2, Chapter 22 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate | Moderate-to- high evidence it doesn't help | High (hypoglycemia) | Low-to-moderate | N/A

Morbidity outcomes have also been assessed. Trials of IIT failed to demonstrate consistent benefits in reducing renal failure or length of stay. The effects of IIT on infection are mixed. The 2001 Van den Berghe SICU trial did find IIT reduced the incidence of sepsis,10 whereas the NICE-SUGAR trial did not.13 Trials also reported a variety of other infection-related outcomes, including wound infections, pneumonia, and urinary tract infection. A pooled analysis of these trials found a nonsignificant reduction in infection, though the results were quite heterogenous (RR 0.68; 95% CI 0.36 to1.30, I^2^ = 56.3%, P=0.033).12

Several trials have reported results since January 2010 (the end of the search period of our systematic review). Two trials found no benefit of IIT on neurologic or mortality outcomes in patients with traumatic brain injury or stroke.14,15 One trial did find postoperative IIT reduced wound infections in diabetic patients who had undergone partial gastrectomy (7.6% v 18.4%, p = 0.03), but the trial had several methodologic flaws.16 Finally, the recent RABBIT 2 trial was among the first to compare the effects of a subcutaneous basal-bolus insulin regimen with sliding-scale insulin on health outcomes.17 In this trial, 211 noncritically ill general surgery patients were randomized to either a basal-bolus insulin regimen using insulin glargine and meal-time glulisine or a sliding-scale insulin regimen (whereby fixed doses of insulin are given in response to specific glucose readings), with a goal glucose target in both groups of 100-140 mg/dL. The basal-bolus group achieved significantly better glycemic control and a lower incidence of wound infections (2.9% vs. 10.3%, p = 0.05), but several methodologic issues, including poor outcome ascertainment methods and no blinding of outcome assessors, threaten the validity of results.

## What Are the Harms of the Patient Safety Practice?

The main harm of IIT is hypoglycemia. Insulin has a narrow therapeutic window: Underuse may fail to resolve potentially risky hyperglycemia, whereas overly aggressive insulin use can lead to severe hypoglycemia. Nearly all 31 trials in our recent systematic review reported that IIT was associated with excess risk of hypoglycemia.12 Our meta-analysis of 10 trials found that IIT was associated with a six-fold increased risk of severe hypoglycemia, defined as glucose <40 mg/dL (RR 6.00; 95% CI 4.06 to 8.87; I^2^ = 57.9%; p<0.001) (Figure 2).12 The few trials published since we did the searches for our review corroborated these findings.14-16

Figure 2, Chapter 22 Risk for hypoglycemia in studies of intensive insulin therapy in various inpatient settings

Figure taken from Kansagara, 2011^12^

Kansagara D, Fu R, Freeman M, Wolf F, Helfand M. Intensive insulin therapy in hospitalized patients: a systematic review. Ann Intern Med. Feb 15 2011; 154. Permission granted from the American College of Physicians (Annals of Internal Medicine is the original source of the material).

Figure 2 is a forest plot of 10 studies assessing one harm of intensive insulin therapy, hypoglycemia. The figure is described in the section, “What are the harms of the Patient Safety Practice?” as follows: “Our meta-analysis of 10 trials found that IIT was associated with a six-fold increased risk of severe hypoglycemia, defined as glucose <40 mg/dL (RR 6.00; 95% CI 4.06 to 8.87; I2 = 57.9%; p<0.001) (Figure 2).” This figure is taken, with permission, from the 2011 article by Kansagara and colleagues, published in Annals of Internal Medicine.

The consequences of hypoglycemia in hospitalized patients may be severe. Several MICU studies found excess risk-adjusted mortality and/or extended length of stay among patients experiencing one or more episodes of severe hypoglycemia.18-22 However, these studies reported few in-hospital adverse effects of hypoglycemia during IIT, though many critically ill patients in these studies were sedated, which limits the completeness of neurologic assessment.

## How Has the Patient Safety Practice Been implemented, and in What Contexts?

The safety of IIT may depend on intervention and implementation characteristics of the IIT protocols. In addition to the IIT trials reviewed above, we reviewed an additional 40 insulin protocol studies that did not report health outcomes in order to better understand how intervention and implementation characteristics of protocols impact safety. These protocol studies differed in terms of patient characteristics, target glucose ranges, the time required to achieve the target glucose levels, the definition and incidence of hypoglycemia, the rationale or algorithm used for adjusting the insulin rates, the methods used to assess effectiveness, and the methods of glucose monitoring.12 Nevertheless, some themes emerge from a review of these protocol studies.

The vast majority of studies evaluated intravenous insulin infusions; fewer examined the effects of subcutaneous insulin protocols. Protocols were most widely tested in ICU populations (both surgical and medical); few studies occurred in general medical or surgical ward settings. Most of the studies were single-center studies of insulin infusion protocols iteratively developed by a local group of providers. The rate of hypoglycemia in these studies was, in general, lower than that seen in IIT trials evaluating health outcomes.

### Glucose Targets

Not surprisingly, we found that protocols targeting higher blood glucose ranges were generally associated with lower rates of hypoglycemia. This observation echoes findings from the trial literature in which insulin infusions were used to target strict (80-110 mg/dL) or moderate (140-200 mg/dL) glucose goals. The rates of severe hypoglycemia were substantially higher in the strict glucose target groups.

We also found protocols that achieved mean blood glucose <120 mg/dL were not consistently safe, even when clinicians used relatively sophisticated computerized algorithms.23,24 Two observational studies evaluated the safety of phasing in progressively stricter glucose targets over time.25,26 One of these was a large single-center retrospective study evaluating the effects of an increasingly aggressive IIT policy in the ICU.25 The authors found a nearly four-fold increase in the incidence of hypoglycemia as the institution moved from no insulin protocol to IIT with a target of 80-130 mg/dL and finally to a target of 80-110 mg/dL.25 The infusion protocol details were not available. A second study of a relatively simple infusion protocol reported a doubling of the rate of severe hypoglycemia as the glucose target moved from 120-150 mg/dL to 80-110 mg/dL, although the overall rate of severel hypoglycemia remained less than 5 percent.26

### Insulin Dosing Factors

The factors used to guide insulin dosing may also be important. Some protocols use only current blood glucose levels to guide dosing, whereas others attempt to anticipate insulin needs based on measures of insulin sensitivity. For example, one recent observational study examined an insulin-resistance-guided protocol in which cardiac surgery patients were assigned to one of six insulin resistance categories.27 The insulin dosing adjustments depended on the category to which each patient was assigned. Hourly arterial blood glucose monitoring was used along with changes in medications and patient condition to determine subsequent changes to insulin resistance category. The authors found that such an approach reduced the rates of both hypoglycemia and hyperglycemia. The SPRINT protocol used a similarly complex approach and also found reductions in hyperglycemia and hypoglycemia in critically ill patients.28

Other reviews speculate that better protocols incorporate bolus insulin doses, account for the direction and rate of glucose change, and make allowances for “off-protocol” adjustments. However, these conclusions are not based on direct comparisons of protocols.29,30

### Computerized Protocols

Most protocols studied have used a paper-based algorithm to guide nurses in making insulin dose adjustments and timing glucose measurements. In recent years, computer-based algorithms have become available and, in 2010, the first RCT comparing these algorithms to a paper-based algorithm was reported.31 This multicenter trial of 153 MICU patients compared a paper-based algorithm to the computerized Glucommander system, which directed insulin dosing and glucose monitoring timing using glucose measurements at the patients' bedside. The glucose target was 80-120 mg/dL. Patients in the computer-algorithm group had fewer instances of marked hyperglycemia (glucose > 200 mg/dL, 11.7% vs. 25%, p = 0.05, but a similar rate of severe hypoglycemia (< 40 mg/dL:, 3.9% vs. 5.6%, p = NS). An older observational study of the same computerized system had reported similar results.32 However, a recent small observational study found only minor improvements in glucose control using a computerized protocol and no change in hypoglycemia rates.33 This study also found that using the computerized protocol led to more frequent glucose testing and insulin dose adjustments. Finally, another recent observational study found that fewer dosing errors occurred with a computer-based protocol than with a paper-based protocol.34

### Continuous Glucose Monitoring

Recently, studies have also examined the use of continuous glucose monitoring devices, although none have tested their use outside of small, single-center populations. In a single-center RCT of 124 MICU patients, a subcutaneous continuous glucose monitoring strategy did not improve glycemic control but did reduce the rate of severe hypoglycemia (1.6% vs. 11.5%, p = 0.03).35 One observational study evaluated a closed-loop glycemic control device, which continuously monitors glucose and automatically delivers insulin and glucose, and found no hypoglycemic events.36

### Glucose Monitoring Site

Capillary blood glucose is the most common source for glucose monitoring. However, it has several notable limitations to its accuracy, which, in turn, affect the safety of IIT. Capillary blood sampling is less dependable than arterial sampling in critically ill patients for several possible reasons, including low perfusion pressure, use of vasopressors, and low pH.37-40 The rate of agreement between capillary and whole blood samples is particularly low in the hypoglycemic range.41,42 Capillary blood testing also tends to overestimate glucose levels in anemic patients, which could lead to overaggressive use of insulin to achieve tight glucose control. One recent study found high rates of measurement error in patients with hematocrit less than 34 percent; the investigators suggested a mathematical correction factor, but it has yet to be tested on a wide scale.43

### Nutrition

Most insulin protocols neither coordinate insulin dosing with patient nutrition nor provide detailed nutritional guidance. In one RCT, 337 critically ill patients were randomized to either a carbohydrate-restrictive strategy or an insulin infusion regimen targeted to blood glucose levels of 80-120 mg/dL.44 Although the glucose level achieved in the carbohydrate-restrictive group was higher than in the infusion group (144 vs. 134 mg/dL, p = 0.03), the difference was modest and the rate of hypoglycemia was substantially lower in the carbohydrate-restrictive group (3.5% vs. 16%, p < 0.01). The results suggest that more-intensive nutritional strategies may be a promising adjunct, or alternative to, IIT. An observational study of the SPRINT protocol, which directly prescribes both insulin dosing and dietary intake, found that it improved glycemic control and reduced the risk of severe hypoglycemia.28

### Sliding Scale Insulin

Although most trials evaluating health outcomes of IIT have used insulin infusions to achieve blood glucose control, subcutaneous insulin is more often used in real-world settings, especially in general ward patients. Subcutaneous sliding scale insulin (SSI) regimens have several theoretical disadvantages when used as the sole method for inpatient glycemic control. For that reason, various researchers have called for a reduction in the widespread use of SSI approaches.45,46

Very few controlled trials have compared SSI with basal-bolus subcutaneous insulin regimens in which both long-acting and meal-time insulin are provided. The multicenter RABBIT 2 surgery trial17 and several small, single-center trials in general medical47-49 and gastric bypass populations50 found that basal-bolus regimens were more effective in lowering blood glucose than SSI, although both strategies had similar rates of hypoglycemia. The RABBIT 2 surgery trial is the only one to have reported the effects of basal-bolus insulin on health outcomes.17

## Are There Any Data About Costs?

No studies evaluating the cost-effectiveness of IIT incorporate findings from trials reported within the past few years. Several earlier studies suggest that IIT is cost-effective, but these studies relied on findings from older studies that had found cost reductions from shorter length of stay and lower risk of costly complications such as infections. However, as noted above, such benefits have not been replicated consistently in more recent trials.

The incremental impact of IIT on resource utilization is unclear. Some studies have suggested that costs are relatively low. For instance, the cost attributable to IIT in cardiac surgery patients in one center were estimated to be $138 per patient.51 Because nurses are typically responsible for glucose monitoring and insulin adjustments, implementing IIT protocols might require more nursing time and effort. One large ICU cohort study found that ITT implementation did not change either nurse:patient ratios or nursing hours.52 By contrast, a multi-center ICU study using more detailed time-in-motion observations found that the nurse-led intensive glucose monitoring and insulin dosing adjustments were burdensome and costly. The authors estimated that nursing personnel could spend up to 2 hours on IIT-related activities for a given patient per 24-hour period; this level of effort totaled $182,488 for nurses' salaries and about $58,500 for supplies in cost over 1 year.53

## Are There Any Data About the Effect of Context on Effectiveness?

All IIT strategies involve frequent insulin dose adjustments and glucose monitoring; these tasks are usually performed by nursing staff and guided by a protocol. Above, we detailed the protocol characteristics that may affect safety, but, because of the frequent human input required, careful implementation strategies and training may also be important to execute IIT safely. Most large IIT trials (see Table 1) did not provide much detail about the clinical context within which they had implemented their IIT interventions. Only two trials specified explicit nursing training before the start of the study.19,54

The high rates of hypoglycemia in recent multicenter IIT trials, such as NICE-SUGAR, may provide some information about implementation of IIT protocols.13 Some have argued that, in general, the protocols used in IIT trials are difficult to implement safely across multiple centers because of the lack of specific instructions, the simplicity of inputs used to guide insulin dosing, and the relative lack of clinical expertise that nurses would gain with IIT in each study site.55 Van den Berghe and colleagues used a simple infusion protocol in their 2001 SICU study, but theirs was a single-center study in which the investigators were practicing clinicians and the nursing staff had more opportunity to develop clinical expertise with the protocol because all patients were treated in one setting.10

In our review of observational studies and smaller IIT trials, we could indirectly glean similar lessons about implementation. Furnary and colleagues acknowledged the importance of local physician champions, an iterative process, and nursing buy-in to the successful implementation of their IIT protocol in cardiac surgery patients.56 They gradually lowered glucose targets from 200 mg/dL to 100-150 mg/dL over 15 years. The rate of deep sternal wound infections dropped with use of IIT, although theirs was an uncontrolled study, and they did not report overall hypoglycemia rates. In contrast, another institution went from no glycemic control policy to a normal glucose target over 5 years in a large population of critically ill patients (n = 10,456); these investigators reported markedly increased rates of hypoglycemia and a trend to increased mortality.25 These results may well reflect the difficulty with broad, rapid implementation of aggressive glucose control practices.

## Conclusions and Comment

The use of IIT to achieve very tight blood glucose control does not reduce short-term mortality in MICU patients (high strength of evidence) or SICU patients (moderate strength of evidence). It increases the risk of severe hypoglycemia in all settings (high strength of evidence). The lack of consistent benefit from very tight blood glucose control and the increased risk of hypoglycemia has led to recommendations for a moderate blood glucose target of 140-200 mg/dL in ICU populations.57 However, it is unknown whether implementation of IIT protocols targeted to moderate blood glucose levels (140-200 mg/dL) with low rates of hypoglycemia improves health outcomes. Despite the lack of evidence to support a specific blood glucose target, many organizations continue to recommend moderate blood glucose control in inpatients because of the association of high blood glucose with infection, poor wound healing, dehydration, and other complications. Although glycemic control protocols remain an important part of quality inpatient care, the lack of clear and consistent evidence of benefit underscores that minimization of hypoglycemia is of paramount importance in the implementation of any glycemic control protocol.

Based on data from a review of insulin protocols and of trials evaluating the health outcome effects of IIT, the following emerge as important issues to consider when implementing IIT protocols:

- The glucose target is important. Glucose targets in the normal range (80-110 mg/dL) markedly increase the risk of severe hypoglycemia and do not improve health outcomes. Higher glucose targets (e.g., 140-200 mg/dL) can be safely achieved with careful IIT implementation.
- The clinical factors used to guide insulin dosing are important. Very simple protocols based only on current and past glucose levels may be difficult to replicate safely across institutions. Protocols incorporating some estimate of a patient's insulin sensitivity may be safer and more effective than those that ignore these factors.
- Newer technologies such as continuous glucose monitoring and computerized protocols may improve glycemic control. However, the evidence base is limited. Whether these technologies reduce hypoglycemia rates remains unclear. The cost of such technology has not been adequately assessed.
- In critically ill patients, capillary blood glucose can be markedly inaccurate, particularly in the hypoglycemic range. Clinicians should exercise caution using capillary blood glucose measurements in these patients and in patients with anemia.
- IIT protocols should be coupled to patient nutrition whenever possible because failure to modify IIT dosing in response to discontinuities in nutritional intake can increase the risk of hypoglycemia. Additionally, some nutritional interventions may, themselves, be effective in reducing the risk of hypoglycemia.
- In surgical patients, weight-based subcutaneous insulin protocols using both basal and bolus insulin may reduce infection rates more than sliding-scale-only insulin. The comparative effects of different subcutaneous insulin regimens has not been well studied in non-surgical populations.
- IIT is a complex endeavor requiring buy-in from nurses and physicians. Implementation of IIT in a given setting is likely best done iteratively, with multidisciplinary involvement and training, and using real-time data to inform continuous quality improvement of the process.

## References

1 Umpierrez GE, Isaacs SD, Bazargan N, You X, Thaler LM, Kitabchi AE. Hyperglycemia: an independent marker of in-hospital mortality in patients with undiagnosed diabetes. [see comment]. J Clin Endocrinol Metab. Mar. 2002;87(3):978-982. [pmid: 11889147].
2 Levetan CS, Passaro M, Jablonski K, Kass M, Ratner RE. Unrecognized diabetes among hospitalized patients. Diabetes Care. Feb. 1998;21(2):246-249. [pmid: 9539990].
3 Furnary AP, Gao G, Grunkemeier GL, et al. Continuous insulin infusion reduces mortality in patients with diabetes undergoing coronary artery bypass grafting. [see comment]. J Thorac Cardiovasc Surg. May. 2003;125(5):1007-1021. [pmid: 12771873].
4 Pomposelli JJ, Baxter JK 3rd, Babineau TJ, et al. Early postoperative glucose control predicts nosocomial infection rate in diabetic patients. JPEN J Parenter Enteral Nutr. Mar-Apr. 1998;22(2):77-81. [pmid: 9527963].
5 Bochicchio GV, Sung J, Joshi M, et al. Persistent hyperglycemia is predictive of outcome in critically ill trauma patients. [erratum appears in J Trauma. 2005 Nov;59(5):1277-8]. J Trauma. May. 2005;58(5):921-924. [pmid: 15920404].
6 Capes SE, Hunt D, Malmberg K, Gerstein HC. Stress hyperglycaemia and increased risk of death after myocardial infarction in patients with and without diabetes: a systematic overview. [see comment]. Lancet. Mar. 4. 2000;355(9206):773-778. [pmid: 10711923].
7 Capes SE, Hunt D, Malmberg K, Pathak P, Gerstein HC. Stress hyperglycemia and prognosis of stroke in nondiabetic and diabetic patients: a systematic overview. [see comment]. Stroke. Oct. 2001;32(10):2426-2432. [pmid: 11588337].
8 Clement S, Braithwaite SS, Magee MF, et al. Management of diabetes and hyperglycemia in hospitals. [erratum appears in Diabetes Care. 2004 Mar;27(3):856 Note: Hirsh, Irl B [corrected to Hirsch, Irl B]; dosage error in text]. Diabetes Care. Feb. 2004;27(2):553-591. [pmid: 14747243].
9 Institute for Health Care Improvement. Establish a glycemic control policy in your ICU. www.ihi.org/IHI/Topics/CriticalCare/IntensiveCare/Changes/IndividualChanges/EstablishaGlycemicControlPolicyinYourICU.htm. 2008.
10 van den Berghe G, Wouters P, Weekers F, et al. Intensive insulin therapy in the critically ill patients. N Engl J Med. Nov. 8. 2001;345(19):1359-1367. [pmid: 11794168].
11 Ingels C, Debaveye Y, Milants I, et al. Strict blood glucose control with insulin during intensive care after cardiac surgery: impact on 4-years survival, dependency on medical care, and quality-of-life. Eur Heart J. Nov. 2006;27(22):2716-2724. [pmid: 16608860].
12 Kansagara D, Fu R, Freeman M, Wolf F, Helfand M. Intensive insulin therapy in hospitalized patients: a systematic review. Ann Intern Med. Feb. 15. 2011;154(4):268-282. [pmid: 21320942].
13 NICE-SUGAR Study, Finfer S, Chittock DR, et al. Intensive versus conventional glucose control in critically ill patients. N Engl J Med. Mar. 26. 2009;360(13):1283-1297. [pmid: 19318384].
14 Green DM, O'Phelan KH, Bassin SL, Chang CWJ, Stern TS, Asai SM. Intensive versus conventional insulin therapy in critically ill neurologic patients. Neurocrit Care. Dec. 2010;13(3):299-306. [pmid: 20697836].
15 Coester A, Neumann CR, Schmidt MI. Intensive insulin therapy in severe traumatic brain injury: a randomized trial. J Trauma. Apr. 2010;68(4):904-911. [pmid: 20032790].
16 Cao SG, Ren JA, Shen B, Chen D, Zhou YB, Li JS. Intensive versus conventional insulin therapy in type 2 diabetes patients undergoing D2 gastrectomy for gastric cancer: a randomized controlled trial. World J Surg. Jan. 2011;35(1):85-92. [pmid: 20878324].
17 Umpierrez GE, Smiley D, Jacobs S, et al. Randomized study of basal-bolus insulin therapy in the inpatient management of patients with type 2 diabetes undergoing general surgery (RABBIT 2 surgery). Diabetes Care. Feb. 2011;34(2):256-261. [pmid: 21228246].
18 Krinsley JS, Krinsley JS. Association between hyperglycemia and increased hospital mortality in a heterogeneous population of critically ill patients. [see comment]. Mayo Clin Proc. Dec. 2003;78(12):1471-1478. [pmid: 14661676].
19 Arabi YM, Dabbagh OC, Tamim HM, et al. Intensive versus conventional insulin therapy: a randomized controlled trial in medical and surgical critically ill patients. Crit Care Med. Dec. 2008;36(12):3190-3197. [pmid: 18936702].
20 Devos P, Preiser JC, Melot C. Impact of tight glucose control by intensive insulin therapy on ICU mortality and the rate of hypoglycaemia: final results of the GLUCONTROL study. Intensive Care Med. 2007;33(Supplement 2):S189.
21 Brunkhorst FM, Engel C, Bloos F, et al. Intensive insulin therapy and pentastarch resuscitation in severe sepsis. The New England journal of medicine. Jan. 2008;358(2):125-139. [pmid: 18184958].
22 Hermanides J, Bosman RJ, Vriesendorp TM, et al. Hypoglycemia is associated with intensive care unit mortality. Crit Care Med. Jun. 2010;38(6):1430-1434. [pmid: 20386307].
23 Dortch MJ, Mowery NT, Ozdas A, et al. A computerized insulin infusion titration protocol improves glucose control with less hypoglycemia compared to a manual titration protocol in a trauma intensive care unit. JPEN J Parenter Enteral Nutr. Jan-Feb. 2008;32(1):18-27. [pmid: 18165443].
24 Toschlog EA, Newton C, Allen N, et al. Morbidity reduction in critically ill trauma patients through use of a computerized insulin infusion protocol: a preliminary study. J Trauma. Jun. 2007;62(6):1370-1375. discussion 1375-1376. [pmid: 17563651].
25 Treggiari MM, Karir V, Yanez ND, Weiss NS, Daniel S, Deem SA. Intensive insulin therapy and mortality in critically ill patients. Crit Care. 2008;12(1):R29. [pmid: 18312617].
26 Taylor BE, Schallom ME, Sona CS, et al. Efficacy and safety of an insulin infusion protocol in a surgical ICU. J Am Coll Surg. Jan. 2006;202(1):1-9. [pmid: 16377491].
27 Caddell KA, Komanapalli CB, Slater MS, et al. Patient-specific insulin-resistance-guided infusion improves glycemic control in cardiac surgery. Ann Thorac Surg. Dec. 2010;90(6):1818-1823. [pmid: 21095317].
28 Chase JG, Shaw G, Le Compte A, et al. Implementation and evaluation of the SPRINT protocol for tight glycaemic control in critically ill patients: a clinical practice change. Critical Care. 2008;12(2).
29 Meijering S, Corstjens AM, Tulleken JE, Meertens JHJM, Zijlstra JG, Ligtenberg JJM. Towards a feasible algorithm for tight glycaemic control in critically ill patients: a systematic review of the literature. Crit Care. Feb. 2006;10(1):R19. [pmid: 16469124].
30 Wilson M, Weinreb J, Hoo GW, Wilson M, Weinreb J, Hoo GWS. Intensive insulin therapy in critical care: a review of 12 protocols. Diabetes Care. Apr. 2007;30(4):1005-1011. [pmid: 17213376].
31 Newton CA, Smiley D, Bode BW, et al. A comparison study of continuous insulin infusion protocols in the medical intensive care unit: computer-guided vs. standard column-based algorithms. J Hosp Med. Oct. 2010;5(8):432-437. [pmid: 20945468].
32 Juneja R, Roudebush C, Kumar N, et al. Utilization of a computerized intravenous insulin infusion program to control blood glucose in the intensive care unit. Diabetes Technol Ther. Jun. 2007;9(3):232-240. [pmid: 17561793].
33 Barletta JF, McAllen KJ, Eriksson EA, et al. The effect of a computer-assisted insulin protocol on glycemic control in a surgical intensive care unit. Diabetes Technol Ther. Apr. 2011;13(4):495-500. [pmid: 21355721].
34 Lee A, Faddoul B, Sowan A, Johnson KL, Silver KD, Vaidya V. Computerisation of a paper-based intravenous insulin protocol reduces errors in a prospective crossover simulated tight glycaemic control study. Intensive Crit Care Nurs. Jun. 2010;26(3):161-168. [pmid: 20430622].
35 Holzinger U, Warszawska J, Kitzberger R, et al. Real-time continuous glucose monitoring in critically ill patients: a prospective randomized trial. Diabetes Care. Mar. 2010;33(3):467-472. [pmid: 20007948].
36 Yatabe T, Yamazaki R, Kitagawa H, et al. The evaluation of the ability of closed-loop glycemic control device to maintain the blood glucose concentration in intensive care unit patients. Crit Care Med. Mar. 2011;39(3):575-578. [pmid: 21178768].
37 Atkin SH, Dasmahapatra A, Jaker MA, Chorost MI, Reddy S. Fingerstick glucose determination in shock. Ann Intern Med. Jun. 15. 1991;114(12):1020-1024. [pmid: 2029097].
38 Critchell CD, Savarese V, Callahan A, Aboud C, Jabbour S, Marik P. Accuracy of bedside capillary blood glucose measurements in critically ill patients. Intensive Care Med. Dec. 2007;33(12):2079-2084. [pmid: 17763842].
39 Tanvetyanon T, Walkenstein MD, Marra A. Inaccurate glucose determination by fingerstick in a patient with peripheral arterial disease. Ann Intern Med. Nov. 5. 2002;137(9):W1. [pmid: 12416976].
40 Juneja D, Pandey R, Singh O. Comparison between arterial and capillary blood glucose monitoring in patients with shock. European Journal of Internal Medicine. Jun. 2011;22(3):241-244. [pmid: 21570641].
41 Kanji S, Singh A, Tierney M, Meggison H, McIntyre L, Hebert PC. Standardization of intravenous insulin therapy improves the efficiency and safety of blood glucose control in critically ill adults. Intensive Care Med. May. 2004;30(5):804-810. [pmid: 15127193].
42 Desachy A, Vuagnat AC, Ghazali AD, et al. Accuracy of bedside glucometry in critically ill patients: influence of clinical characteristics and perfusion index. Mayo Clin Proc. Apr. 2008;83(4):400-405. [pmid: 18380985].
43 Pidcoke HF, Wade CE, Mann EA, et al. Anemia causes hypoglycemia in intensive care unit patients due to error in single-channel glucometers: methods of reducing patient risk. Crit Care Med. Feb. 2010;38(2):471-476. [pmid: 19789438].
44 de Azevedo JRA, de Araujo LO, da Silva WS, de Azevedo RP. A carbohydrate-restrictive strategy is safer and as efficient as intensive insulin therapy in critically ill patients. J Crit Care. Mar. 2010;25(1):84-89. [pmid: 19327317].
45 Metchick LN, Petit WA Jr., Inzucchi SE. Inpatient management of diabetes mellitus. [see comment]. Am J Med. Sep. 2002;113(4):317-323. [pmid: 12361818].
46 Cheung NW, Chipps DR. Sliding scale insulin: will the false idol finally fall?. Intern Med J. Sep. 2010;40(9):662-664. [pmid: 20862784].
47 Umpierrez GE, Smiley D, Zisman A, et al. Randomized study of basal-bolus insulin therapy in the inpatient management of patients with type 2 diabetes (RABBIT 2 trial). [see comment]. Diabetes Care. Sep. 2007;30(9):2181-2186. [pmid: 17513708].
48 Dickerson LM, Ye X, Sack JL, Hueston WJ. Glycemic control in medical inpatients with type 2 diabetes mellitus receiving sliding scale insulin regimens versus routine diabetes medications: a multicenter randomized controlled trial. Ann Fam Med. May-Jun. 2003;1(1):29-35. [pmid: 15043177].
49 Korytkowski MT, Salata RJ, Koerbel GL, et al. Insulin therapy and glycemic control in hospitalized patients with diabetes during enteral nutrition therapy: a randomized controlled clinical trial. Diabetes Care. Apr. 2009;32(4):594-596. [pmid: 19336639].
50 Datta S, Qaadir A, Villanueva G, Baldwin D. Once-daily insulin glargine versus 6-hour sliding scale regular insulin for control of hyperglycemia after a bariatric surgical procedure: a randomized clinical trial. Endocr Pract. May-Jun. 2007;13(3):225-231. [pmid: 17599852].
51 Furnary AP, Wu Y, Bookin SO. Effect of hyperglycemia and continuous intravenous insulin infusions on outcomes of cardiac surgical procedures: the Portland Diabetic Project. Endocr Pract. Mar-Apr. Suppl 2. 2004;10:21-33. [pmid: 15251637].
52 Krinsley JS. Effect of an intensive glucose management protocol on the mortality of critically ill adult patients. [see comment][erratum appears in Mayo Clin Proc. 2005 Aug;80(8):1101]. Mayo Clin Proc. Aug. 2004;79(8):992-1000. [pmid: 15301325].
53 Aragon D. Evaluation of nursing work effort and perceptions about blood glucose testing in tight glycemic control. Am J Crit Care. Jul. 2006;15(4):370-377. [pmid: 16823014].
54 De La Rosa GD, Donado JH, Restrepo AH, et al. Strict glycaemic control in patients hospitalised in a mixed medical and surgical intensive care unit: a randomised clinical trial. Critical Care. 2008;12(5):R120. [pmid: 18799004].
55 Van den Berghe G, Schetz M, Vlasselaers D, et al. Clinical review: Intensive insulin therapy in critically ill patients: NICE-SUGAR or Leuven blood glucose target?. J Clin Endocrinol Metab. Sep. 2009;94(9):3163-3170. [pmid: 19531590].
56 Furnary AP, Zerr KJ, Grunkemeier GL, Starr A. Continuous intravenous insulin infusion reduces the incidence of deep sternal wound infection in diabetic patients after cardiac surgical procedures. [see comment]. Ann Thorac Surg. Feb. 1999;67(2):352-360. discussion 360-352. [pmid: 10197653].
57 Qaseem A, Humphrey LL, Chou R, Snow V, Shekelle P, Clinical Guidelines Committee of the American College of P. Use of intensive insulin therapy for the management of glycemic control in hospitalized patients: a clinical practice guideline from the American College of Physicians. Ann Intern Med. Feb. 15. 2011;154(4):260-267. [pmid: 21320941].
58 Bilotta F, Caramia R, Paoloni FP, et al. Safety and efficacy of intensive insulin therapy in critical neurosurgical patients. Anesthesiology. Mar. 2009;110(3):611-619. [pmid: 19237874].
59 Van den Berghe G, Wilmer A, Hermans G, et al. Intensive insulin therapy in the medical ICU. N Engl J Med. Feb. 2. 2006;354(5):449-461. [pmid: 16452557].
60 Preiser JC, Devos P, Ruiz-Santana S, et al. A prospective randomised multi-centre controlled trial on tight glucose control by intensive insulin therapy in adult intensive care units: the Glucontrol study. Intensive Care Med. Oct. 2009;35(10):1738-1748. [pmid: 19636533].
61 Malmberg K, Ryden L, Efendic S, et al. Randomized trial of insulin-glucose infusion followed by subcutaneous insulin treatment in diabetic patients with acute myocardial infarction (DIGAMI study): effects on mortality at 1 year. J Am Coll Cardiol. Jul. 1995;26(1):57-65. [pmid: 7797776].
62 Malmberg K, Ryden L, Wedel H, et al. Intense metabolic control by means of insulin in patients with diabetes mellitus and acute myocardial infarction (DIGAMI 2): effects on mortality and morbidity. Eur Heart J. Apr. 2005;26(7):650-661. [pmid: 15728645].
63 Gray CS, Hildreth AJ, Sandercock PA, et al. Glucose-potassium-insulin infusions in the management of post-stroke hyperglycaemia: the UK Glucose Insulin in Stroke Trial (GIST-UK). Lancet neurol. May. 2007;6(5):397-406. [pmid: 17434094].