# Preventing In-Facility Pressure Ulcers

## How Important Is the Problem?

Pressure ulcers (PUs) are preventable, but PU rates continue to escalate alarmingly fast. In fact, between 1995 and 2008, the incidence of PUs increased by as much as 80%.1 Estimates of incidence are high for both acute and long-term care patients. Current estimates indicate that 2.5 million patients will develop a PU, and 60,000 U.S. patients will die from complications related to hospital-acquired PUs.2 A 2009 National Center for Health Statistics (NCHS) Data Brief reported about 11% of nursing home residents had PUs (in 2004), stage 2 being the most common.3

Preventing PUs is important not only to protect patients from harm, but also to reduce costs of care. Estimates suggest that PU treatment costs could be as high as $11 billion annually.4 Patients with PU-related morbidity need more care and resources and have longer inpatient stays. In some cases, late-stage PUs lead to life-threatening infections. Because of the ever-increasing number of obese, diabetic, and elderly patients, PU rates are predicted to continue to rise. To gather available information about the effectiveness of PU prevention programs, we searched CINAHL, the Cochrane Library, EMBASE, MEDLINE, and PreMEDLINE from 1981 to 2011, in addition to searching gray literature. We identified 454 abstracts from which 87 full-text articles were reviewed in more detail, yielding 47 articles contributing data to this review.

## What Is the Patient Safety Practice?

Sources for patient safety practices to prevent pressure ulcers included evidence- and consensus-based guidelines, how-to guides from national organizations, and comprehensive frameworks from well-recognized wound organizations.

A national campaign by Advancing Excellence in America's Nursing Homes provides an implementation guide that includes “efficient, consistent, evidence-based approaches to address the prevention and minimization of pressure ulcers.”5 The coalition recommends that nursing homes seeking to identify areas for improvement in processes and practices should verify whether the homes' current policies and protocols are consistent with current evidence-based approaches, (i.e., new National Pressure Ulcer Advisory Panel [NPUAP] guidelines). In 2008, the Joint Commission included healthcare-associated PU prevention as a National Patient Safety Goal (NPSG) for long-term care. “Elements of performance” for this NPSG include using a validated risk assessment tool, reassessing PU risk at intervals defined within the organization, and educating staff on how to identify risk for and prevent PUs.6 The Institute for Healthcare Improvement describes six key evidence-based care components in its How-to Guide: Prevent Pressure Ulcers. Essential elements include making risk and skin assessments (upon admission and daily), managing moisture, optimizing nutrition and hydration, and minimizing pressure.7

A search of the National Guideline Clearinghouse™ identified recommendations to prevent and manage PUs by many well-respected organizations including the Wound, Ostomy and Continence Nurses Society (WOCN).8 Preventive interventions based on Level B evidence include scheduling regular repositioning and turning for bed- and chair-bound individuals and using pressure redistribution surfaces in the operating room for high-risk individuals.

We identified two frameworks for Patient Safety Practices that appear to thoroughly embody components used in PU prevention initiatives today (see Table 1 and Table 2 following). A recent systematic review9 describes the Indiana State Department of Health's classification of PU initiative components, as follows:

- Organization components include team makeup, policies and procedures, ongoing quality evaluation processes, educating staff, utilizing “skin champions,” and the development and system-wide communication of the written care plan
- PU prevention components include risk and skin assessment, moisture management, nutrition and hydration optimization and pressure management
- Care coordination components include the establishment of regular meetings to facilitate communication, collegiality, and learning

Table 1, Chapter 21 Components of pressure ulcer prevention trials in U.S. hospitals, 2000 to 2011

Study | Implement Protocol | Review Wound Care Products | Upgrade Automated Systems | Integrate New Reporting | Education/Training | Risk Assessment Tool | Skin Champion | Multi-disciplinary Team | Audit and Feedback
Lynch and Vickery 2010^11^ | X | X | | X | X | | | X | X
Young et al. 2010^12^ | X | X | X | X | X | X | X | X | X
Bales et al. 2009^b,d,13^ | X | | X | | X | | | X | X
Chicano and Droishagen 2009^b,14^ | X | X | | X | X | X | | X | X
Walsh et al. 2009^15^ | X | X | | | X | X | | X
Dibsie L. 2008^16^ | X | X | | X | X | | X | | X
McInerney J. 2008^17^ | X | X | X | X | X | X | | X | X
Ballard et al. 2007^18^ | X | X | X | X | X | | X | | X
Catania et al. 2007^19^ | X | | | | X | X | | X | X^a^
LeMaster K. 2007^b,c,20^ | X | | X | X | X | X | | | X
Courtney et al. 2006^21^ | X | X | | X | X | X | X | | X
Gibbons et al. 2006^d,22^ | X | | | | X | | | X | X
Hiser et al. 2006^23^ | X | | | | X | X | | | X
Lyder et al. 2004^24^ | | | X | | X | | | X | X^a^
Stier et al. 2004^25^ | X | X | | | X | X | | X | X

[image] = reported a significant reduction in pressure ulcer rates

a Audit only.

b Reduced prevalence/incidence to zero.

c Describes role of CNS as a direct consultant.

d Describes use of incentives.

Table 2, Chapter 21 Components of pressure ulcer prevention trials in long term care, 2000 to 2011

Study | Implement Protocol | Upgrade Automated Systems | Integrate New Reporting | Education/ Training | New Assessment Tool | Use of Outside Consultants^*^ | Skin Champion | Multi-disciplinary Team | Audit and Feedback
Horn et al. 2010^26^ | X | X | X | X | X | X | X | X | X
Rantz et al. 2010^b,27^ | X | X | | | | X
Milne et al. 2009^d,28^ | X | X | X | X | X | X | X | X | X
Tippet A. 2009^c,d,29^ | X | | X | X | X | X | X | X | X
Rosen et al. 2006^c,30^ | X | | | X | | X | | X | X
Abel et al. 2005^31^ | X | | | X | X | X | X
Ryden et al. 2000^32^ | X | | | X | | | X
Rantz et al. 2001^a,33^ | X | | X | X | | X | | | X

[image] = reported a significant reduction in pressure ulcer rates

* Examples include advanced practice nurses,28 physician wound consultant,29 and state quality improvement program staff.27,31 Services included identifying team leaders/multidisciplinary teams,26 streamlining documentation,26 educating staff,29 providing evidence-based tools (i.e., assessment cards),31 team leadership and technical assistance29

a Randomized controlled trials.

b Nonrandomized controlled trial.

c Describes use of incentives.

d Reviewed wound care products.

The ABCDE of Pressure Ulcer Incidence Reduction Initiatives was outlined at the 12th NPUAP Biennial Conference held on February 2011. The initiatives were described as: administrative support backed by support at the patient care level; bundling care practices and having an identifiable theme; creating a culture of change, commitment, and communication; documentation of PU prevention practices must be visible; and education is essential.10

## Why Should This Patient Safety Practice Work?

Age, immobility, incontinence, inadequate nutrition, sensory deficiency, multiple comorbidities, circulatory abnormalities, and dehydration are a handful of the more than 100 factors that have been identified as placing adults at risk for developing PUs.2,34 In addition to having many risk factors, PUs can develop very quickly. PUs have been documented as developing in just 1 hour.12

However, despite the many risk factors and the quick development of PUs, they can be successfully prevented with several strategies. Improvements in care processes (e.g., skin assessments) and patient outcomes (e.g., incidence, length of stay) have resulted from single-component PU prevention initiatives such as a turn-team nursing program,35 an educational intervention,36 and a tracking system.37 A recent systematic review concluded that using support surfaces, repositioning the patient, optimizing nutritional status, and moisturizing sacral skin are appropriate strategies for preventing PUs.4

Use of intervention bundles has also been effective in eliminating PUs.38 The concept of bundling care practices is credited to the Institute for Healthcare Improvement. Defined as a structured way of improving processes of care and patient outcomes, a bundle typically includes three to five evidence-based practices that “when performed collectively and reliably, have been proven to improve patient outcomes.”39 Although successful in and of themselves, bundling care practices is only one of several important components listed in the ABCDE of Pressure Ulcer Incidence Reduction Initiatives.

During the NPUAP keynote address, former president Elizabeth Ayello mentions the importance of a partnership between administration and bedside caregivers. She describes the administration's role in making PU prevention a priority by providing adequate resources and infrastructure and listening to staff about how to implement best practices.10 Jankowski and Nadzam (2011) concur on the importance of facilities' administration in their quest to identify gaps, barriers, and solutions in implementing PU prevention programs.9 Additionally, NPUAP lists “creating a culture of change, commitment and communication” as paramount to reduction initiatives. “Training and communication among turn-team members, the enterostomal staff, and clinical nursing directors was critical for the success” of one initiative.35

Both single and multicomponent programs described the importance of adding documentation and education into PU prevention initiatives. Challenges encountered during the implementation of a tracking system included manpower resources and documentation.37 Jankowski and Nadzam (2011) reported that major barriers to protocol implementation were related to documentation. They indicated that although “every hospital had a written PU protocol and used the Braden Scale for Predicting Pressure Sore Risk, none of the hospitals routinely included the risk scores or PU prevention care plans in shift-to-shift reports, RNs-NA reports, RN-physician communications, or other handoffs between hospital staff (e.g., staff nurse to transporter).”9 A 2009 ECRI Institute risk analysis on PUs40 recommends that “to establish mechanisms of effective communication between facilities, include the following for all transfer documentation: (1) standardized location of information; (2) current risk assessment; (3) skin and observed wound assessment; and (4) current interventions (if applicable).”

## What Are the Beneficial Effects of the Patient Safety Practice?

We limited our research to studies implementing multicomponent initiatives in acute (k = 15) and long-term care settings (k = 8) in the U.S. from 2000 to the present (see evidence tables in appendix). Study designs were mostly time series assessments of changes before, during, and after implementation of the intervention. Other study designs included randomized controlled (k=2)27,33 and controlled before-and-after (k=1).32 A majority of the studies focused on universal prevention (all risk levels); one focused on high-risk patients.26 Pressure ulcers were the primary focus of 20 studies and part of a comprehensive approach in three.27,32,33

The review group agreed not to assess risk of bias or rate the strength of evidence for those reviews primarily focused on implementation. Therefore, in this section, we briefly summarize the primary results; subsequently, we provide detailed assessments of the implementation efforts.

### Acute Care

Evidence presented below on PU prevention programs implemented in the acute care setting is based primarily on one systematic review (Soban 2011) of nurse-focused quality improvement (QI) initiatives.41 Of the 39 studies included in the review, 12 met our inclusion criteria. Additionally, we discuss three other studies that were published since the Soban review was completed.

The Soban review41 had three objectives: describe the intervention strategies used, describe the process and outcome measures reported, and examine the interventions' effects on outcomes. Study findings were categorized as processes of care (e.g., staging of acquired stage 2 PUs) and/or patient outcomes (e.g., PU incidence). Eleven studies reported patient outcomes; only one study24 reported both. Because the review included limited data, we accessed information directly from the studies.

First, we examine intervention effects on several processes of care reported in one multihospital QI collaboration overseen by the Connecticut Quality Improvement Organization, Qualidigm. In 2004, Lyder et al.24 reported a 2-year follow-up on 14 measures, seven of which were process of care measures. Four plan-do-study-act (PDSA) improvement cycles implemented at 17 hospitals resulted in significant increases in identifying high-risk patients (20.3% vs. 35.3%, p<0.001); repositioning of bed-bound patients every 2 hours or every hour in chair-bound patients (50.9 vs. 56.9, p = 0.01); use of nutritional consults in malnourished patients (34.3% vs. 48.6%, p<0.001); and staging of acquired stage 2 or greater PUs (22.4% vs. 44.2%, p<0.01). No statistically significant findings were reported for the remaining processes of care (including staging of acquired stage 1 PUs) or hospital-acquired incidence rate (baseline vs. follow-up; 20.6 vs. 20.8, p=0.90).

Five of the 11 remaining studies reported in the Soban review conducted nurse-focused initiatives facility- or system-wide. A majority of studies reported on prevalence or incidence measures; both types of measures have been described as useful in assessing and improving patient care Catania indicates that a declining incidence of PUs would indicate that a prevention program is working to decrease new PU cases, while a declining prevalence indicates that the treatment strategy was also having an impact on the duration of PUs.19 Several studies reported that initiatives reduced prevalence or incidence to zero.

After a 10-month implementation of the SKIN ([underlined: S]urfaces, [underlined: K]eep the Patient Turning, [underlined: I]ncontinence Management, [underlined: N]utrition) bundle, Gibbons et al.22 reported a 90% reduction (5.7% to 0.448%) in prevalence at the Nation's largest Catholic and nonprofit health system.22 Similar reductions were reported at a 548-bed, two-hospital system in Southwest Florida:17 a 5-year trend analysis indicated a significant reduction in PU prevalence (overall [-81%] and ulcers located on the heel [-90%]) after “proactive assessment and management of at‐risk patients.” One study reported zero PU prevalence and incidence after 1 year of a nurse-focused initiative at a 300-bed community hospital.13 Other benefits listed were optimal patient care and avoiding the cost of treating stage 3 or 4 ulcers.

In 2006, Courtney (SOS program/Six Sigma methodology) reported that one 710-licensed bed, multisite, not-for-profit hospital reduced the PU incident rate from 9.4% to 1.8% over 3 years. Incidence was reduced by 6.3% after only 1 quarter.21 Two years earlier, Stier et al.25 reported reducing incidence by more than 50% at a 5,600 bed nonprofit health care system.

Significant improvements were also reported from initiatives implemented in patient care units, with two studies reporting zero prevalence postimplementation. In 2006, a two-unit intensive care unit (ICU) significantly reduced PU prevalence (34% to 8%), noting that National Database of Nursing Quality Indicators (NDNQI) benchmark data were “instrumental in helping our unit focus on PU prevention, ultimately leading to improved patient outcomes.”18 Catania et al.19 reported reducing PU prevalence by more than 50% due to implementing the Pressure Ulcer Prevention Protocol Interventions in five in-patient units at one cancer hospital. From September 2004 (baseline) to June 2006 (postimplementation), the percentage of patients with all types of PUs and with hospital-acquired pressure ulcers (HAPUs) was reduced to 4% and 2%, respectively. NDNQI benchmarks at the time were 12.65% for all ulcers and 6.84% for HAPUs.

In a 2007 study, preimplementation PU prevalence rates for a pulmonary and oncology unit were 9% and 12%, respectively. LeMaster20 reported that nurse-focused QI initiatives reduced prevalence in these two hospital units to zero. Rates were reduced from 9.2% to 6.6% in five units in one Florida hospital.23 One medical ICU, which reportedly had the highest HAPU prevalence (average of 29.6%) among the participating units, reduced prevalence to zero.

Dibsie et al.16 reported a facility-wide reduction in percentage of patients with stage 2 or greater HAPUs (4.2% vs. 3.2%) in four adult critical care units (54 beds) at two U.S. hospitals. Rates for the surgical intensive care unit, however, did not improve over time (6.1% pre- and postimplementation). A 23-month initiative (Chicano 2007) at a 25-bed intermediate care unit reduced incidence.14

Benefits described in three separate studies (Walsh et al., Young et al., and Lynch and Vickery) included a reduction in prevalence and incidence and improvements in processes of care. In 2009, Walsh et al. reported a reduced PU prevalence from 12.8% to 0.6% from an 18-month initiative. Walsh also reported increased focused communication among patient caregivers; once improvements were noticed, clinician's behavior and clinical processes improved.15 Young et al. reported several successes, including streamlining online policies (from 7 to 1) and reduction in time spent documenting skin care. Young also reported “clinically relevant reductions” in development of nosocomial PUs.12

In one year, PU rates were reduced by 82.8% (2.8% to 0.48%) at one rehabilitation hospital. Lynch and Vickery reported that streamlining documentation increased timely and accurate completion of documentation from 60% to 90% in 90 days. This facility also increased patient/family involvement in patients care by providing an educational brochure and reviewing interventions on admission.11

### Long-Term Care

A total of eight studies met our inclusion criteria in their evaluation of multicomponent programs to prevent PUs in long-term care facilities. Study duration ranged from 6 months to 6 years. Among these eight programs, four reported significant reduction in PU incidence or prevalence rates.

In 2010, Horn et al. reported on three main outcome measures.26 First, they considered prevalence of PUs using Centers for Medicare & Medicaid Services (CMS) quality measures (QMs). Based on data from seven facilities, they report that the CMS high-risk PU QM decreased from 13.0% (baseline) to 8.7% (12 months postimplementation). A second outcome of interest was the number of in-house acquired PUs. The average number of in-house PUs (all stages) per facility was reduced by 62% (12.1 [baseline] to 4.6 [postimplementation]). Lastly, Horn et al. reported a 53.2% reduction in the average number of certified nursing assistant (CNA) documentation forms and a mid-90% completeness rate of CNA documentation.

Tippet et al. reported that nosocomial PU ulcers were eliminated after 6 months.29 They also reported an 86% reduction in average incidence: 5.19% (preinitiative) vs. 0.73% (postinitiative); p<0.0001. By the end of the fourth year, both incidence and prevalence were reduced by 99%.

In 2006, Rosen et al. reported a significant reduction in PU incidence.30 The percentages of patients identified as “high-risk” were 22.3% and 28.0% at the baseline and intervention periods, respectively. Significant reductions in PU incidence were reported for stage 1 and beyond (P<0.001) and stage 2 and beyond (p<0.05). However, these improvements were not sustained during the postintervention periods when no weekly reports (indicating completion of training) were provided; no targets or goals were established; and no financial incentives were offered to staff.

One RCT was conducted in three privately owned facilities in the midwestern United States.32 This 6-month study evaluated the effectiveness of advanced practice nurses (APNs) to successfully implement scientifically based protocols for PUs and other clinical problems. The APNs delivered treatment in two facilities; in the third facility, patients received usual care. At 6 months, the percent of APN-treated patients with PUs was significantly reduced (19.8% vs. 3.5%; p=0.04). The percentage of patients with PUs for the usual care group was also reduced, although not significantly.

Four studies conducted in long-term care facilities reported no significant findings from primary analysis. At 12 months, Rantz et al.27 reported relative improvements in high-risk PU scores (negative indicating improvement) were -53%, -12%, -5%, and +435% for Group 1, 2, 3, 4, respectively. At 24 months, relative improvement was -3%, -8%, +59%, and +105% for these same groups, respectively.

Abel et al. describe results from a 2-year study conducted in 20 sites.31 They report a significant improvement for 8 of 12 PU-related quality indicators; however, only a trend toward a lower incidence of facility-acquired PUs (x^2^_MH_ = 3.66, p = 0.06) was observed. Facilities also fell short in two other key measurements: proportion of high-risk residents with facility-acquired PUs whose care plan intervention reflects treatment orders and proportion of skilled nursing facilities that have a wound protocol.

Milne et al.28 reported several successes. The facility-acquired PU prevalence rate at baseline was 41%. PUs were reduced to <3% on two units due to increased monitoring of modified nasal cannula (pulmonary unit) and increased attentiveness to heel offloading, support surfaces, and proper positioning (SCI/trauma unit). Of the 396 charts reviewed, fewer than 1% had missing data. A review of 45 patient charts showed that wound teams consistently determined staging and wound etiology in more than 90% of cases. The facility-acquired PU rate was reduced by 37% within 1 year postimplementation.

In 2001, Rantz et al.33 randomly assigned 87 facilities to receive workshop plus feedback reports (Group 1); workshop, feedback reports, and clinical consult (Group 2); and control (Group 3). Primary analysis indicated no statistically significant findings for prevalence of stage 1-4 PUs or prevalence of stage 1-4 PUs (low-risk residents).

## What Are the Harms of the Patient Safety Practice?

There have been no reported harms of the PSP.

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

We examined studies of multicomponent PU prevention programs for information on contexts. The description of contexts is limited: most reports contain information on certain contextual factors but lack information on other factors. The limited evidence available is summarized below.

### Use of a Model or Theory

Of the 15 studies conducted in acute care facilities, only four programs described a model or theory as the basis of their implementation strategy. The PDSA framework was a methodology used in 17 hospitals in Connecticut.24 The four PDSA improvement cycles involve identifying the problem and designing an intervention (Plan), implementing change (Do), evaluating the collected data (Study), and implementing what was learned (Act). Lyder et al. indicated that these processes should be developed rapidly to “sustain momentum in changing behaviors, procedures, and policies as quickly as possible.” Although described as being used on a “hospital-wide scale,” this framework may also be applied on a smaller scale such as a hospital unit.

Courtney et al. integrated Six Sigma methodologies into treatment processes developed for a multisite, not-for-profit facility. Described as a data-driven quality strategy for improving processes, DMAIC consists of five interconnected steps: (1) defining the problem, (2) measuring the performance; (3) analyzing the data, (4) improving the process, and (5) controlling change.42 Young12 stressed the importance of empowering staff at point of care, which “suggests a model of shared governance where decisions are made at the point of service.” A shared governance model was also employed at an Illinois-based intermediate care unit.14 Use of quality council members or a self-managing work team has been described as a second-generation shared governance model. According to Nursingworld.com, a self-managing work team such as the quality council members are “jointly responsible for achieving goals, lead themselves, and thus have authority and control over the work and access to information.”43

Of the eight long-term care studies, one study27 referenced effectiveness of similar components in a previous study;33 another described using the failure mode and effects analysis (FMEA) developed by the U.S. military.28 FMEA is defined as a systematic process for identifying potential design process failures before they occur to eliminate them or minimize risk. The basis for one program was Havelock's (1974) model of effective research utilization. This model is described as integrating knowledgeable resource individuals as links between relevant sources of scientific knowledge and the user (e.g., staff).32

### External Factors Motivating Attention to Pressure Ulcer Prevention

Most studies in acute care facilities reported feeling pressure from impending changes in CMS reimbursement. Specifically, subsequent to passage of the Deficit Reduction Act of 2005, CMS will no longer allow higher DRG (diagnosis-related group) payments for patients with stage 3 and 4 HAPUs. Catania reported that one dedicated cancer hospital was responding to the identification of two stage-4 PUs and evidence from the NDNQI survey that the prevalence of PUs in the hospital exceeded the national benchmark by close to 50%.19 A 25-bed intermediate-care unit indicated that identification of high prevalence rates, nursing peer reviews, chart audits, and unit observations played an important role in the hospital's response.14 Lynch mentioned that the facility experienced an upward trend in PUs on two units.11

One 528-bed nonprofit facility, at which prevalence of HAPUs was lower than national norms, set out to eliminate HAPUs completely.22 In 2006, Courtney et al.21 described the emergence of new guidelines from the American Nurses Association and the Agency for Healthcare Research and Quality as showing a “revitalized interest” in preventing and treating PUs. Additionally, studies using the Nursing Care Quality Initiative guidelines revealed high prevalence of PUs (13%) and lack of documentation and management. Two critical incidents (not specified), concerns within individual units, and inconsistent documentation were listed as external motivators by Dibsie et al.16 Additionally, “the frequency with which concerns and incidents were discussed, but went unreported within the internal reporting system” were of concern. Young reports stakeholder commitment to improve patient outcomes and a goal “to be recognized as a quality provider of patient services.”12

External factors influencing the staff at one 151-bed Midwest skilled facility were a G-level citation (a deficiency judged to cause actual harm to residents) and State survey deficiencies.29 This facility recorded PU prevalence and average incidence rates as high as 25% and 23.9%, respectively. One facility reported receiving multiple citations from the Department of Health.30 Abel et al.31 indicated that the 20 participating facilities were identified from 143 Medicare-certified skilled nursing facilities with high rates of PUs despite a high volume of residents receiving preventive care.

### Structural Organizational Characteristics

Organizational characteristics described in all studies included financial and academic status, location, and size. Bed range for acute care studies ranged from 18 to 800. Settings included a community hospital, a multisite academic medical center, and a cancer hospital. Implementation studies included as few as two units and as many as 17 hospitals.18,24

Long-term care programs were conducted in not-for-profit facilities;26,30 a privately owned facility,32 a Midwest-skilled nursing facility,29 and a mix of for-profit, not-for-profit, and governmental facilities.27,33 Other studies were conducted in Medicare-certified skilled nursing facilities31 and in a 108-bed long-term acute care facility.28

Two studies published in 2010^26,27^ were conducted in seven and three states, respectively; 20 studies were conducted in one state. The number of facilities included in each study ranged from 1 to 87. Bed size ranged from 1 to 60 in one study33 and from 44 to 432 in another.26 Only the highest-risk units (three maximum) participated in one program.26 Five studies indicated prior experience with QI or presence of electronic medical record (EMR).26-28,30,33 Two studies reported on organizational complexity.30,32 Of the 23 included studies, only two studies described patient characteristics.29,32

### Teamwork/Leadership

Although a majority of studies utilized a multidisciplinary team, skin champions were described as key team members. Studies set in acute care settings described use of certified wound ostomy continence nurses (CWOCNs),13,18,23 staff registered nurses or patient care technicians,21 clinical nurse specialists (CNSs),19 and a collaboration between CNSs and wound ostomy nurses20 in this role. Of eight studies set in long-term care settings, skin champions were designated in five studies;26,28,29,31,32 in two studies, advanced practice nurses served in this role.28,32

Three studies included lengthy descriptions of leadership within their facilities. Stier et al. described leadership support to multidisciplinary teams at a 5,600-bed nonprofit New York-based health care system.25 Teams consisting of clinical experts from 18 facilities convened to openly discuss the various risk assessment tools and facility protocols in place. Multidisciplinary teams agreed to develop a uniform policy, skin care formulary, and specialty bed contract. “System leadership (e.g., nurse executives, quality management directors, and senior physicians) provided support to the team at both the system and facility level” vis-a-vis “resources, ensured staff orientation and education, maintained quality control programs, and continually assessed actions to improve performance through system-wide care committee meetings.”

Dibsie16 described the importance of teamwork and leadership at a multisite academic medical center. Discussions on serious skin-related issues were held with unit nursing management, immediate senior nursing management, and selected peers. Discussions later involved a larger group of managers and clinical specialists after “it became evident that the issues crossed many areas and could be better handled by the group together.” When necessary, senior management stepped in to stress “the importance of resolving issues related to prevention…throughout the organization.”

Young et al. described a change in leadership at a 540-bed acute care facility in Indiana. “Clinicians were initially wary of management's intent for clinician involvement. Their hesitation was attributed to past experiences when some clinicians joined the task force to attain required activities relating to clinical advancement or in response to a manager's request.” As a result of mandates that the new skin team be clinician-led, “the majority of the original task force members left…The few remaining committee members were charged with selecting new task force members who could serve as unit champions.”12

### Patient Safety Culture

Several studies provided a glimpse of the patient safety culture that existed before programs were implemented. Staff at a 528-bed nonprofit hospital believed “that PUs were unavoidable in complex, critically ill patients.” At this facility, chart reviews of 30 patients who developed PUs indicated that 87% of the time a nutritional consult had been ordered, but nutritional recommendations were only followed 35% of the time.22 McInerney17 reported a high prevalence of PUs at a two hospital system; greater than 50% of ulcers were located on the heel. Further review revealed that physician and nurse reluctance to use a rigid boot was the root of the problem.

Lyder et al. reported that most hospitals participating in a multihospital QI collaboration did not believe that PU prevention was a huge priority.24 In 2010, Lynch11 discussed several process issues at a 166-bed acute rehabilitation facility. A review of 2007 data indicated many misidentified PUs at admission, incomplete and inconclusive skin assessments, incorrect staging, and inconsistent documentation of interventions.

At the unit level, staff at one medical ICU also believed that PUs were inevitable among seriously ill patients.23 Staff at a two-unit ICU did not believe the prevalence data, stating the higher acuity patients “were more likely to develop skin breakdown.”18 Accountability, knowledge deficit, and communication deficits were identified as root causes of reported high incidence/prevalence at one teaching hospital. Incomplete initial and ongoing skin assessments, inconsistent implementation of prevention interventions, and lack of coordination among staff were cited as examples of preimplementation safety culture.21 Lastly, analysis of survey results at one 25-bed intermediate care unit revealed that admission documentation did not identify patients with an increased risk for developing PUs.14

In the long-term care setting, five studies reported minimal information on patient safety culture at the organizational level.26,28-31 One study included information at the unit level.28 Abel31 reported that facilities were plagued by inadequate assessments and data omissions associated with risk. Milne indicated that one facility had above-average PU prevalence, used a faulty EMR that was inconsistently used by clinicians, and had deficient documentation of risk assessment.28

### Implementation Tools

Below, we describe examples of unique tools that were used for audit and feedback, education and training, monitoring progress, identifying specific groups of patients at risk, and streamlining products and processes in more than 20 PU prevention initiatives. For a complete listing of implementation tools, see evidence tables in the appendix.

#### Audit and Feedback

Audit and feedback were mentioned as key elements in initiatives implemented in long-term care studies. In one study, facilitators provided direct feedback to CNAs regarding data inconsistencies by unit and by shift to help track progress.26 Real-time management feedback in Rosen et al.30 consisted of a prominently displayed graphic thermometer tracking weekly PU incidence, and positive ($10 reward) or negative reinforcement (termination). Weekly informal feedback by nursing supervisors,29 formal weekly walk-rounds11 and frequent patient positioning audits were also used during implementation.29 See below for more detailed descriptions included in acute care studies:

- “Identification of skin breakdown must be reported within the electronic system, and weekly surveillance summaries need to be shared with administration.”14
- Feedback was provided during weekly SKIN operations meeting where unit leadership reported compliance with the SKIN bundles and related issues.22
- “The team provided clinical staff with consistent and frequent feedback about the results of prevalence studies for their specific units so they could benchmark their results over time. This immediate and ongoing feedback helped engage staff members in their program and allowed them to take credit for the improved clinical outcomes. To reinforce the positive changes, medical ICU staff members were given a certificate for the Most Improved Unit.”23
- While providing feedback to nursing staff, the CNSs “attempted to balance compliments for a job well done with recommendations for improvement.”20

#### Education and Training

The majority off the 23 studies reported including some form of education or training. Training was reported as mandatory in four studies.12,13,29,30 Only one study reported on duration of training (40 minutes).30 Unique tools used in education and training sessions are described as follows:

- Guest speakers discussed new concepts and educated physicians about the CWOCN's role, level of clinical expertise, and best-practice wound care interventions.23
- During 30-minute mandatory continuing education sessions, participants sit on bedpans that act as a reminder that PUs can occur within as brief a time as 1 hour.12 Compensation was provided to staff participating on their own time. Educational content was tailored for RNs, LPNs, secretaries, and CNAs. A post-test survey measured effectiveness of presentation.
- Staff education included critical thinking using case studies and role-playing exercises.19
- Staff participated in skin-care training using an interactive video.30

#### Identifying Specific Groups of Patients at Risk

- McInerney et al.17 reported that using computerized charting and order entry helped identify specific groups of patients at risk for developing PUs. A consult with a specially trained nurse is automatically generated when patients are identified as high/very high risk. Consults are also generated for two other patient groups considered high risk (e.g., patients placed on a ventilator and patients receiving hemodialysis).

#### Monitoring Progress

- To monitor progress at a large 528-bed hospital, a SKIN Bundle Compliance Tool was developed. Nutrition-related items include noting completion of a nutrition consult, orders written, and orders carried out.22
- One rehabilitation hospital posted report cards on every unit allowing staff to track progress against other units and unit goals.11

#### Streamlining Products and Processes

- A large nonprofit health care system streamlined a skin product line, trimming it from 100 products to 24. Standardizing products controlled costs and reduced training.25
- Four critical care units conducted extensive in-service education on a new wound care product line and made vendor support available. Vendor clinical experts were available to educate staff on new products. Dibsie recommends informing clinicians when modifications are made to the skin protocol or product line.16
- Nursing leadership, nursing staff and those from other disciplines (e.g., nutritionists, respiratory therapists) compared current policies and procedures to clinical practice guidelines. The Director of Informatics facilitated revisions12 of seven existing policies into one.

### Barriers

Reported barriers to implementing PU prevention programs included expansion of the initiative to a larger scale,16 unmotivated staff,13,14,19 staff turnover,26,31-33 staff resistance,24,31 limited resources,12 inconsistent documentation,13,20,31 difficulties in exporting data,26and miscommunication between electronic systems.20 One facility also faced increased PU rates.28 Examples of barriers described and ultimate solutions are as follows:

#### Acute Care

- Dibsie16 reported that expanding initiatives from a 20-bed critical care unit to all nursing units in two sites provided an extra challenge. Obstacles included the coordination of a skin committee, difficulty in coordinating schedules, and keeping abreast of new equipment that can contribute to PU development.
- Chicano14 reported a challenge motivating staff who were relatively uninvolved in planning and implementing initiatives. Perseverance of council members encouraged the staff to finally “accept the concept of shared governance and acknowledge that it can positively influence patient care.”
- During the early stages of one initiative, staff members were not sufficiently committed. Although a QI analysis indicated that two stage 4 PUs were the result of “inconsistencies in or lack of documentation, staff awareness and assessment,” staff members denied that the PUs were due to poor nursing care. Catania indicated that “overcoming it took additional education, mentoring, and support at the unit level.”19
- As reported by Lyder et al.,24 hospitals identified as a major barrier the view that PU prevention was a nursing issue. The medical staff was reportedly the most resistive when asked to play a role in PU prevention. Due to this mindset, considerable time was spent “re-educating various disciplines about their roles in PU prevention.”
- Young et al. reported that clinicians complained of time constraints, insufficient computer resources, and competing goals. To address these concerns, clinicians were allocated 4 paid hours to carry out responsibilities related to PU prevention, and web access to library resources was added to the organization's intranet.12
- Bales et al.13 reported unmotivated staff and lack of proper reporting and documentation. Monthly to quarterly campaigns were launched to maintain staff motivation. Nursing units that had zero HAPUs were recognized and awarded during campaigns.
- LeMaster20 reported Braden scores (a scale for predicting PU risk) were not documented at 100% according to policy. Patients were missed because of a communication failure between two different electronic documentation systems. To address this, the facility transitioned to a single, universal electronic record system.

#### Long-Term Care

- Horn et al. reported difficulties at one of 11 facilities in exporting data elements.26 As a result, the facility could create only one of four possible clinical decision-making reports. Additional issues concerned the preparation of documents—specifically forms needing the resident's study ID number and faxing forms for report generation. Staff turnover, especially for director of nursing, also seemed to slow program momentum. To overcome these barriers, suggestions included adding new CNA documentation processes into orientation programs, phasing in use of documentation, and developing a strong multidisciplinary team to lead improvement efforts. Ryden et al.32 reported barriers to their implementation program included high turnover (range of 11% to 45%) of unlicensed staff.
- Barriers faced by 20 facilities in Texas included incomplete admission assessments, staff reverting to previously unsuccessful practices, and inappropriate use of monitoring systems. Staff resistance, staff turnover, and variations in new staff orientation also affected program implementation. Monthly visits by a State Quality Improvement Organization (TMF Health Quality Institute) and improving performance may have helped resolve these issues.31
- Barriers reported by Milne et al.28 included a climb in PU rates once strict monitoring of processes was leveled off from weekly to monthly for 1 month. To overcome this barrier, the wound team increased presence on the units, monitored charts more closely, provided feedback to staff, and scheduled biweekly prevalence rounds.
- Rantz 2001^33^ indicated that staff turnover, especially the nurse coordinator, cancellations of site visits at the last minute, and teams “mired in the MDS [minimum data set] assessment process and coding issues” impeded initiatives. To address some of these issues, multiple nurses were assigned responsibility for processes, accomplishments were posted, and a quality manager was placed on staff to support care delivery.

### Sustainability

Several acute and long-term care facilities reported sustainability of PU prevention programs. Conducting quarterly prevalence studies and continually monitoring all HAPUs were key to sustaining improvements at a large nonprofit health system. A focus on skin pigmentation and the development of a skin fragility assessment tool were the most recent strategies introduced.22 McInerney17 indicated that publicizing improvements in PU rates will keep staff focused on prevention efforts.

One 710-bed multisite facility reported that the “overall culture change at the medical center remains a work in progress. Therefore, PU incidence continues to be a measurement used in organization-wide scorecards and staff bonus programs.” Measuring performance routinely has since become a priority facility-wide and at sister facilities.21 LeMaster20 reported a request by staff members for items to provide both visual and auditory clues to sustain improvements at their facility. Dibsie et al.16 reported “staff members continued to meet on a monthly basis to discuss skin issues, participate in quarterly prevalence data collection, and learn from the medical center's expert WOCNs as well as from one another.”

Walsh indicates the importance of maintaining gains, including keeping current regarding “initiatives for improved patient safety, changes in regulatory mandates, and changes in EBP [evidence-based practices].” At a 540-bed acute care facility, RNs and LPNs must demonstrate competency annually; monthly updates provided via intranet to staff include product changes.12

One rehabilitation hospital printed quarterly newsletters and attached them to paychecks. The newsletters described findings, results, and new initiatives in PU management.11 According to Bales et al.,13 sustainability requires awareness of key management skills and priorities, such as strong leadership, involvement of staff in decision-making, and a desire to foster interdisciplinary relationships.

Eleven long-term care facilities across seven states stated that “managing the manual data collection, faxing forms to the project office and creating clinical reports for distribution back to the facilities on a weekly basis” could not be maintained over the long term. By date of study publication, more than 70 additional facilities were participating in the On-Time program.26 A wound care coordinator position29 and a wound care committee32 were established to help sustain program gains in two long-term care programs. Lastly, one 108-bed LTC facility noted that two wound coordinators provided additional education. Monthly review of documentation and the presence of multiple PU prevention interventions on units also helped to sustain improvements.28

### Lessons Learned

Several programs implemented facility-wide reported key lessons learned. Recommendations from one large nonprofit health system include the following: (1) use current leadership to support staff; (2) disregard a spike in reported skin breakdown, which is probably due to staff's increased awareness, education and reporting; (3) make staff accountable for success of initiatives; (4) do not assume that the knowledge base between disciplines is equal; (5) stay on task and celebrate successes.22

Seventeen hospitals reportedly liked the idea that PDSA cycles could be completed using a small number of cases to identify improvement areas and implement potential interventions at a reduced scale before implementing programs at full scale, saving time and human resources.24 Lessons learned in Courtney et al. include the following: (1) identify and involve the process owner (unit manager) and S.O.S. (Safe our Skin) unit champion early in the project; (2) develop a detailed training plan to include delegation and team work; (3) communicate the changes to everyone; (4) streamline the process to make it as easy as possible; (5) celebrate success, give recognition, spread the success; (6) define roles and responsibilities; (7) realize that you cannot fix everything at one time; (8) support and commitment from senior leadership are critical to the success and help to sustain the gains.21

Abel et al. reported lessons learned by 20 Medicare-certified skilled nursing homes while working collaboratively with TMF, a State quality improvement organization.31 A TMF representative provided the following recommendations:

- Strive to transition from quality assurance to QI, moving from defect detection to defect prevention, while making continuous improvement in the process of care delivery.
- Incorporate interventions designed to address barriers to preventive care while sustaining existing processes that have proven effective.
- Publicly recognize front line staff successes.
- Share data often.
- Implement change on one unit/hall at a time to ensure staff buy-in.
- Accept failure in the systems as an opportunity to improve.
- Operationalize systems that use continued measurement to monitor and improve performance that is reported to be below a designated threshold.
- Allow staff to maintain a level of autonomy during design of the intervention.
- Ensure accountability in following agreed-upon process changes.
- Ensure consistency in a formalized staff training/orientation related to documentation requirements.
- Include staff that directly affect the process in the intervention design.44

## Are There Any Data About Costs of Pressure Ulcer Prevention Programs?

Five studies included information on costs of PU prevention programs: two in acute care facilities and three in long-term care facilities. In 2008, McInerney17 indicated millions of dollars in cost savings due to the significant reductions (-81%) in PU prevalence at a two-hospital system in Naples, Florida. A conservative analysis (assuming savings of $3,000 per case) found that this 548-bed system saved “approximately $11.5 million annually as a result of the program.”

A Midwest 710-bed teaching hospital estimated additional cost per case (in 2001) was $3,037, and the additional overall cost related to PU development was $4,877,000. Based on these figures, “a reduction in the number of HAPUs by 50% to 5% would reduce overall costs by $2,438,000.00.” This amount would not preclude the “anticipated significant improvements in patient satisfaction, length of stay/quality, staff awareness of skin integrity issues, and risk management issues.”21

The most recently reported costs in a long-term care setting were from 2010 in a four-group comparison study that assessed the value of a bedside electronic health record PU initiative.27 “Total costs for the 3-year evaluation for the groups of facilities implementing technology increased $15.11 (12.5%) for Group 1 and $16.89 (9.6%) for Group 2, while those for the comparison groups did not.” Rantz et al. attributed cost increases to the cost of technology, including maintenance and support and ongoing staff training to use the EMR system.27

In 2009, a 151-bed Midwest skilled facility described cost savings 4 years after program implementation. The authors estimated cost savings per PU/per month was $1,617; monthly savings, $10,187; and yearly savings greater than $122,000.^29^ Lastly, in 2006, Rosen et al. stated “based on a mean cost of $2700 to treat a single stage II PU,45 reducing the incidence of ulcers by approximately 15 over 12 weeks would yield savings of approximately $40,000. Less than $10,000 was distributed as financial incentives.”

## What Is Known About the Effect of Context on Outcomes?

Several studies directly commented on the effect of context on outcomes, and all studies specifically mentioned the influence of staff on implementation. Dibsie16 reported that “the changes in the climate and practice related to skin care and prevention of breakdown are the direct result of nursing taking ownership of their practice with the support of nursing leaders at all levels.”

Lyder indicated that “focusing pressure ulcer prediction and prevention programs on the nursing staff is limited. Effective pressure ulcer prevention requires a multidisciplinary effort. The PDSA model assists hospitals in working in multidisciplinary teams and places the onus for improvement on the team rather than on a particular discipline.”24 According to Lyder, hospitals found that the most sustainable interventions were those that were institutionalized. For example, two hospitals changed their hospital mattresses to pressure-relieving mattresses. However, interventions that are most dependent on sufficient staffing were more difficult to sustain (for example, ensuring that every resident is turned every 2 hours).24

Bales et al.13 reported that the hospital's managerial style encouraged staff involvement in decision-making about developing a program, and leadership gave strong support to the program and promoted it to both other leaders and hospital staff. Chicano14 reported that “commitment and diligence from the QI team and from the members of the staff's self-governance councils played a significant factor in achieving our goal of reducing HAPU prevalence in our intermediate care unit.”

Contextual factors that Horn et al.26 identified as key to their success were resident participation, use of a multidisciplinary team, and integration of all clinical reports. The facility with the highest reduction in PUs (-82.4%) had 100% involvement of residents. In addition, this facility incorporated all 4 weekly clinical reports into care planning. Two facilities with the lowest reduction in PUs did not involve a multidisciplinary team. This study included only the highest risk units at each facility.

Abel et al. reported that higher QI scoring and greater improvement in scores equaled lower PU incidence rates. He indicated that 10 facilities with the highest quality indicator scores at re-measurement showed a trend toward lower PU incidence rates than the 10 facilities with the lowest QI scores at re-measurement (-4.6% vs. -2.6%) (S = 125.5, p = 0.07). In addition, the 10 facilities with the greatest improvement in QI scores had significantly lower PU incidence rates than the 10 facilities with the least improvement in QI scores (-6% vs. -1.2%) (S = 131.0, P = 0.03). Later, Abel noted that study results demonstrated a relationship between PU incidence rates and improvement in QI scores, suggesting a relationship between the process of care measures and patient outcome (i.e., PU incidence). He adds that “improved performance was primarily noted in measures that were less dependent on staffing, i.e., use of support surfaces and risk assessment tools rather than patient turning.”

Milne et al.28 reported on revisions of care in two units with greatly improved PUs. On a pulmonary focused unit, PUs were observed at the ear/scalp junction of 25% of patients. With the adaption of the nasal cannula, PU rates on the ear/scalp junction were reduced within 2 months to less than 3%. On a separate unit, 33.8% of SCI and trauma patients were suffering from sacral and heel sores due to immobility and sensory deficit. Due to several focused initiatives, including pressure redistribution support surfaces, PU rates dropped to 2.9%, a 30.9% reduction.

Rantz 2001^33^ observed that intensive consultation contributed to a greater improvement in MDS QI measures for several outcome measures, including two focused on PUs.

## Conclusions and Comment

A review of the evidence indicates that a variety of multicomponent initiatives have been implemented in U.S. acute and long-term care settings to prevent PUs. Improvements (many significant) were reported both from comprehensive initiatives (targeting several patient safety concerns) and from those primarily focused on reducing PUs. Successful prevention initiatives were reported regardless of setting (system-, facility-, or unit-wide) or number of components integrated in the initiative. However, evidence indicated that the majority of successful initiatives integrated several core components. Key to improving these measures were the simplification and standardization of pressure-ulcer-specific interventions and documentation, involvement of multidisciplinary teams and leadership, designated skin champions, ongoing education, and sustained audit and feedback for promoting both accountability and recognizing successes.

Several studies commented on the influence of context on outcomes. Useful information was also included on topics such as barriers, solutions to barriers, and issues surrounding sustainability. Key lessons learned include keeping both leadership and staff accountable for the initiative's success, streamlining processes, learning from front-line staff, implementing change one unit at a time, providing feedback, and celebrating successes.

Of the 23 studies included in this review, eight studies (evenly split between acute and long-term care settings) reported on both processes of care and patient outcomes. A majority of these studies reported improvements in processes of care and corresponding improvements in patient outcomes. We did, however, identify two studies that reported significant improvement in several processes of care with little or no improvement in patient outcomes. Future research should focus on the specific preventive measures or processes of care undertaken to better understand their influence on patient outcomes. We also encourage clinicians to report findings regardless of success level and to report strategies to sustain momentum of preventive programs. A summary table is located below (Table 3).

Table 3, Chapter 21 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate | Moderate | Negligible | Moderate | Moderate/Moderate

## References

1 Lyder CH, Ayello EA. Annual checkup: the CMS pressure ulcer present-on-admission indicator. Adv Skin Wound Care. Oct. 2009;22(10):476-84. [pmid: 20026923].
2 Duncan KD. Preventing pressure ulcers: the goal is zero. Jt Comm J Qual Patient Saf. Oct. 2007;33(10):605-10. [pmid: 18030862].
3 Park-Lee E, Caffrey C. Pressure ulcers among nursing home residents: United States, 2004. NCHS Data Brief. Feb. 2009;(14):1-8. www.cdc.gov/nchs/data/databriefs/db14.pdf. [pmid: 19389326].
4 Reddy M, Gill SS, Rochon PA. Preventing pressure ulcers: a systematic review. JAMA. Aug. 23. 2006;296(8):974-84. [pmid: 16926357].
5 Advancing Excellence Steering Committee. Implementation guide: goal 4: reducing high risk pressure ulcers. NH Quality Campaign. 24. www.nhqualitycampaign.org/files/impguides/4_PressureUlcer_TAW_Guide.pdf.
6 Joint Commission. Accreditation program: long term care. National patient safety goals. Oakbrook Terrace (IL). Joint Commission. Jan. 1. 2011:13. www.jointcommission.org/assets/1/6/2011_NPSGs_LTC.pdf.
7 How-to guide: prevent pressure ulcers. Cambridge (MA). Institute for Healthcare Improvement (IHI). 2011. 19. www.ihi.org/knowledge/Knowledge%20Center%20Assets/Tools%20-%20How-toGuidePreventPressureUlcers_0a06721b-7d9b-42f6-8d40-53347fa21b65/HowtoGuidePreventPressureUlcers.pdf.
8 Wound, Ostomy, and Continence Nurses Society (WOCN). Guideline for prevention and management of pressure ulcers. Mount Laurel (NJ). Wound, Ostomy, and Continence Nurses Society (WOCN). 2010. Jun. 1. 96 p. (WOCN clinical practice guideline; no. 2).
9 Jankowski IM, Nadzam DM. Identifying gaps, barriers, and solutions in implementing pressure ulcer prevention programs. Jt Comm J Qual Patient Saf. Jun. 2011;37(6):253-64. [pmid: 21706985].
10 Ayello AE. Keynote: successful pressure ulcer initiatives to reduce pressure ulcer incidence [slide set]. 12th NPUAP Biennial Conference. 2011 Feb. National Pressure Ulcer Advisory Panel. 2011. Feb. www.npuap.org/PDF%20FINAL%20Handout%20Feb%2025%20Ayello%20PRessure%20Ulcer%20Initiatives%20NPUAP%202011%20Las%20Vegas.pdf.
11 Lynch S, Vickery P. Steps to reducing hospital-acquired pressure ulcers. Nursing. Nov. 2010;40(11):61-2. [pmid: 20975436].
12 Young J, Ernsting M, Kehoe A, Holmes K. Results of a clinician-led evidence-based task force initiative relating to pressure ulcer risk assessment and prevention. J Wound Ostomy Continence Nurs. Sep-Oct. 2010;37(5):495-503. [pmid: 20736858].
13 Bales I, Padwojski A. Reaching for the moon: achieving zero pressure ulcer prevalence. J Wound Care. Apr. 2009;18(4):137-144. [pmid: 19349933].
14 Chicano SG, Drolshagen C. Reducing hospital-acquired pressure ulcers. J Wound Ostomy Continence Nurs. Jan-Feb. 2009;36(1):45-50. [pmid: 19155823].
15 Walsh NS, Blanck AW, Barrett KL. Pressure ulcer management in the acute care setting: a response to regulatory mandates. J Wound Ostomy Continence Nurs. Jul-Aug. 2009;36(4):385-8. [pmid: 19609158].
16 Dibsie LG. Implementing evidence-based practice to prevent skin breakdown. Crit Care Nurs Q. Apr-Jun. 2008;31(2):140-9. [pmid: 18360144].
17 McInerney JA. Reducing hospital-acquired pressure ulcer prevalence through a focused prevention program. Adv Skin Wound Care. Feb. 2008;21(2):75-8. [pmid: 18349734].
18 Ballard N, McCombs A, Deboor S, Strachan J, Johnson M, Smith MJ, et al. How our ICU decreased the rate of hospital-acquired pressure ulcers. J Nurs Care Qual. Jan-Mar. 2008;23(1):92-6. [pmid: 18281882].
19 Catania K, Huang C, James P, Madison M, Moran M, Ohr M. Wound wise: PUPPI: the Pressure Ulcer Prevention Protocol Interventions. Am J Nurs. Apr. 2007;107(4):44-52. quiz 53. [pmid: 17413732].
20 LeMaster KM. Reducing incidence and prevalence of hospital-acquired pressure ulcers at Genesis Medical Center. Jt Comm J Qual Patient Saf. Oct. 2007;33(10):611-6. 585. [pmid: 18030863].
21 Courtney BA, Ruppman JB, Cooper HM. Save our skin: initiative cuts pressure ulcer incidence in half. Nurs Manage. Apr. 2006;37(4):36. 38. 40 passim. [pmid: 16603946].
22 Gibbons W, Shanks HT, Kleinhelter P, Jones P. Eliminating facility-acquired pressure ulcers at Ascension Health. Jt Comm J Qual Patient Saf. Sep. 2006;32(9):488-96. [pmid: 17987872].
23 Hiser B, Rochette J, Philbin S, Lowerhouse N, Terburgh C, Pietsch C. Implementing a pressure ulcer prevention program and enhancing the role of the CWOCN: impact on outcomes. Ostomy Wound Manage. Feb. 2006;52(2):48-59. [pmid: 16464994].
24 Lyder CH, Grady J, Mathur D, Petrillo MK, Meehan TP. Preventing pressure ulcers in Connecticut hospitals by using the plan-do-study-act model of quality improvement. Jt Comm J Qual Saf. Apr. 2004;30(4):205-14. [pmid: 15085786].
25 Stier L, Dlugacz YD, O'Connor LJ, Eichorn AM, White M, Fitzpatrick J. Reinforcing organizationwide pressure ulcer reduction on high-risk geriatric inpatient units. Outcomes Manag. Jan-Mar. 2004;8(1):28-32. [pmid: 14740581].
26 Horn SD, Sharkey SS, Hudak S, Gassaway J, James R, Spector W. Pressure ulcer prevention in long-term-care facilities: a pilot study implementing standardized nurse aide documentation and feedback reports. Adv Skin Wound Care. Mar. 2010;23(3):120-31. [pmid: 20177165].
27 Rantz MJ, Hicks L, Petroski GF, Madsen RW, Alexander G, Galambos C, et al. Cost, staffing and quality impact of bedside electronic medical record (EMR) in nursing homes. J Am Med Dir Assoc. Sep. 2010;11(7):485-93. [pmid: 20816336].
28 Milne CT, Trigilia D, Houle TL, Delong S, Rosenblum D. Reducing pressure ulcer prevalence rates in the long-term acute care setting. Ostomy Wound Manage. Apr. 2009;55(4):50-9. [pmid: 19387096].
29 Tippet AW. Reducing the incidence of pressure ulcers in nursing home residents: a prospective 6-year evaluation. Ostomy Wound Manage. Nov. 1. 2009;55(11):52-8. [pmid: 19934464].
30 Rosen J, Mittal V, Degenholtz H, Castle N, Mulsant BH, Hulland S, et al. Ability, incentives, and management feedback: organizational change to reduce pressure ulcers in a nursing home. J Am Med Dir Assoc. Mar. 2006;7(3):141-6. [pmid: 16503306].
31 Abel RL, Warren K, Bean G, Gabbard B, Lyder CH, Bing M, et al. Quality improvement in nursing homes in Texas: results from a pressure ulcer prevention project. J Am Med Dir Assoc. May-Jun. 2005;6(3):181-8. [pmid: 15894247].
32 Ryden MB, Snyder M, Gross CR, Savik K, Pearson V, Krichbaum K, et al. Value-added outcomes: the use of advanced practice nurses in long-term care facilities. Gerontologist. Dec. 2000;40(6):654-62. [pmid: 11131082].
33 Rantz MJ, Popejoy L, Petroski GF, Madsen RW, Mehr DR, Zwygart-Stauffacher M, et al. Randomized clinical trial of a quality improvement intervention in nursing homes. Gerontologist. Aug. 2001;41(4):525-38. [pmid: 11490051].
34 Lyder CH, Ayello EA. Pressure ulcers: a patient safety issue. Patient safety and quality: an evidence-based handbook for nurses. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Apr. 2008:1-33. www.ahrq.gov/qual/nurseshdbk/docs/LyderC_PUPSI.pdf.
35 Hobbs BK. Reducing the incidence of pressure ulcers: implementation of a turn-team nursing program. J Gerontol Nurs. Nov. 2004;30(11):46-51. [pmid: 15575191].
36 Uzun O, Aylaz R, Karadag E. Prospective study: reducing pressure ulcers in intensive care units at a Turkish medical center. J Wound Ostomy Continence Nurs. Jul-Aug. 2009;36(4):404-11. [pmid: 19609161].
37 Zaratkiewicz S, Whitney JD, Lowe JR, et al. Development and implementation of a hospital-acquired pressure ulcer incidence tracking system and algorithm. J Healthc Qual. Nov-Dec. 2010;32(6):44-51. [pmid: 20946425].
38 Gray-Siracusa K, Schrier L. Use of an intervention bundle to eliminate pressure ulcers in critical care. J Nurs Care Qual. Jul-Sep. 2011;26(3):216-25. [pmid: 21278597].
39 What is a bundle? [internet]. Cambridge (MA). Institute for Healthcare Improvement (IHI). 2011 Nov 18. [3 p]. www.ihi.org/knowledge/Pages/ImprovementStories/WhatIsaBundle.aspx.
40 Healthcare risk control: pressure ulcers. Vol. 3, Risk analysis. Plymouth Meeting (PA). ECRI Institute. 2011. May. 21 p. (Nursing; no. 4).
41 Soban LM, Hempel S, Munjas BA, Miles J, Rubenstein LV. Preventing pressure ulcers in hospitals: a systematic review of nurse-focused quality improvement interventions. Jt Comm J Qual Patient Saf. Jun. 2011;37(6):245-52. [pmid: 21706984].
42 What is DMAIC? [internet]. Chicago (IL). iSixSigma. 2011 Nov 10. [1 p]. www.isixsigma.com/index.php?option=com_k2&view=item&layout=item&id=1483&Itemid=369.
43 Anthony MK. Shared governance models: the theory, practice, and evidence. Online J Issues Nurs. Jan. 31. 2004;9(1):7. www.nursingworld.org/MainMenuCategories/ANAMarketplace/ANAPeriodicals/OJIN/TableofContents/Volume92004/No1Jan04/SharedGovernanceModels.html?css=print. [pmid: 14998357].
44 Warren K, Bean G, Abel B, Gabbard B, Bing M. Improvement report: reducing pressure ulcer rates in nursing homes. [internet]. Cambridge (MA). Institute for Healthcare Improvement. 2004. Dec. 2011 Jun 15. [3 p]. www.ihi.org/IHI/Topics/PatientSafety/SafetyGeneral/ImprovementStories/ReducingPressureUlcerRatesinNursingHomes.htm.
45 Xakellis GC, Frantz R. The cost of healing pressure ulcers across multiple health care settings. Adv Wound Care. Nov-Dec. 1996;9(6):18-22. [pmid: 9069752].