# Preventing In-Facility Delirium

## How Important Is the Problem?

Delirium (also known as acute confusional state) refers to an acute decline in attention and cognition that constitutes a serious problem for older hospitalized patients and long-term care residents. Estimated hospital occurrence rates have ranged from 14% to 56% and vary depending upon reason for hospitalization (e.g., urgent surgery, intensive care, general medical admission) and the patient's risk of developing delirium.1 Development of delirium is associated with an increased risk of mortality, postoperative complications, longer hospital and intensive care unit stays, and functional decline.1,2 In addition, delirium presents a significant burden in terms of short and long-term health care costs. A study of 841 patients (age ≥70 years) admitted to non-intensive care general medical units over a three year period at Yale-New Haven hospital found that costs per day were more than 2.5 times higher for patients with delirium compared with those without delirium. The total cost estimates associated with delirium ranged from $16,303 to $64,421 per patient, which the authors extrapolated to national costs ranging from $38 billion to $152 billion each year.1 As these cost estimates were based on data from 1995-1998, the costs of delirium today would be even higher. Accordingly, prevention of delirium is extremely important both for improving patient outcomes and for lowering health care costs.

## What Is the Patient Safety Practice?

Several delirium prevention programs are multifactorial bundles of interventions. In general, the components in the bundle vary across each published evaluation, and the same bundle is rarely evaluated in more than one application (see Appendix D, Table 2). Therefore, the best that can be done is to describe the components most commonly included in bundles that have been found to reduce incident delirium. Based on our review (described later), we identified the following as the most common components of successful bundles:

- Anesthetic protocols
- Assessment of bowel/bladder functions
- Early mobilization
- Extra nutrition
- Geriatric consultation
- Hydration
- Medication review
- Pain management
- Prevention and treatment of medical complications
- Sleep enhancement
- Staff education
- Supplemental oxygen
- Therapeutic cognitive activities/orientation
- Vision and hearing protocols

Additional components have been reported in successful multifactorial bundles. An intervention used in a Swedish university hospital for patients with hip fracture included increased physiological monitoring, avoidance of delays in transfer through different areas of the hospital, daily delirium screening, and avoidance of polypharmacy (as well as several components from the bolded list, including extra nutrition, IV fluid supplementation, pain management, and perioperative/anesthetic period protocols).3 A multifactorial intervention used at another Swedish university hospital for patients with hip fracture included treatment of sleep apnea, prevention and treatment of decubitus ulcers, and measurement of blood pressure along with components from the bolded list, although it is not clear that all of these components were specifically designed to prevent delirium.4

The Hospital Elder Life Program (HELP) or a modified version of HELP was the most frequently-evaluated multifactorial intervention, appearing in three studies.5-7 This program typically consists of six components, including orientation, therapeutic activities, vision and hearing protocols, sleep enhancement, and early mobilization. Two studies (one U.S., one Australian) used proactive geriatric consultation with targeted recommendations (several from the bolded list) based on a structured protocol.8,9

Components that have been used as single interventions include: medical therapy (anesthetics or other drugs believed to lower the risk of delirium), hydration, and music therapy (see Table 3). The overwhelming majority of single interventions consisted of some type of medication; this included Dexmedetomidine for post-operative anesthesia (two studies), Rivastigmine (two studies), Propofol (two studies), Olanzapine (one study), Ketamine (one study), Melatonin (one study), Risperidone (one study), Haloperidol (one study), Donepezil (one study), and Diazepam plus Flunitrazepam plus Pethidine drip infusion (one study).

## Why Should This Patient Safety Practice Work?

Evidence from risk-factor studies suggests that delirium has a multifactorial etiology. Our literature review identified 55 studies of factors associated with delirium occurrence that met inclusion criteria (see Appendix D, Table 1 for individual study data). Collectively, these studies found significant associations between several factors and occurrence of delirium. However, no two studies evaluated the exact same set of factors or found the same combination of significant factors associated with delirium. The risk of bias was moderate in 31 studies and high in 24 studies.

Age was the most commonly evaluated factor, assessed in 34 studies. Twenty studies (58.8%) found a significant association between older age and delirium occurrence, including the two largest studies that evaluated data from more than a million patients recorded in large databases (most of the other studies included between 40-500 patients). These large studies had a high risk of bias due to retrospective design, identification of delirium from ICD-9 codes, and inclusion of prevalent as well as incident cases of delirium in the same analysis, but smaller studies with a moderate risk of bias supported the findings. Since many studies exclusively enrolled older patients (age >65 or >70 years), it may have been more difficult to demonstrate an association in some of these studies (due to restriction of range), which may partially explain the inconsistent findings in the evidence base. Another potential explanation is that some studies may have lacked adequate power to find statistical significance, although this was clearly not the case in all studies that did not have a significant finding. Cognitive impairment or dementia was evaluated in 26 studies; 22 studies (84.6%) found a significant association between this factor and incidence of delirium. Depression was evaluated in 10 studies, but only four (40%) found a significant association with delirium occurrence.

Other patient-specific risk factors that showed a significant association with delirium in more than one study include male gender, multiple medications, comorbidities (e.g., diabetes), pneumonia, various anesthetics, neuropsychiatric drugs (e.g., benzodiazepines), anticholinergics, blood transfusions, abnormal serum chemistry (e.g., urea levels, creatinine levels), apolipoprotein E4 (APOE4), atrial fibrillation, heavy alcohol intake, volume depletion (dehydration), oxygen levels, complications, restraints (rendering patients immobile) and visual impairment. Several studies evaluated patients undergoing specific surgical procedures (e.g., hip repair or replacement, cardiac surgery); some of these studies focused on surgery-specific risk factors (e.g., blood transfusions, intraoperative anesthesia) and evaluated few non-surgical factors.

Given the multifactorial nature of delirium, a patient safety practice designed to assess and remediate multiple factors is believed to be more likely to be effective. Indeed, the list of components in successful delirium prevention bundles targets several factors identified in this list of patient and environmental contributors to delirium. For example, the Hospital Elder Life Program (HELP) specifically targets six risk factors for delirium: cognitive impairment, visual impairment, hearing impairment, sleep deprivation, immobility, and dehydration.7 Of this list, only hearing impairment was not identified as a risk factor by the studies in our evidence base, but this may be because only one of those studies even evaluated it as a possible risk factor.

## What Are the Beneficial Effects of the Patient Safety Practice?

To assess the effects of delirium prevention interventions, we performed a systematic review of six databases (including Medline and CINAHL) from 1999 to 2011 from which we got 587 titles of which 85 were reviewed in detail. From this we identified 31 studies that met inclusion criteria for addressing this question. Fifteen studies evaluated the efficacy of multicomponent interventions (see Appendix D, Table 2), and the remaining 16 studies evaluated single interventions (see Appendix D, Table 3). Most of these studies reported the incidence of delirium following intervention compared with a control arm of usual care treated concurrently or during a period immediately prior to adoption of the new intervention. Some studies of medical therapy used an alternative medical therapy as the comparative arm. Since very few studies used the same intervention, comparison group, study design and/or patient population, meta-analyses were not performed for the majority of interventions.

### Multicomponent Interventions

#### Hospital Inpatient Care

Of the multicomponent intervention studies, two used HELP and a third used a modification of HELP. One was a controlled before-and-after study with a concurrent control group consisting of patients from usual care units7,10; this study had a moderate risk of bias. The remaining two studies were before-and-after studies where the usual care group consisted of patients treated prior to implementation of HELP (historical control)5,6; these studies had a high risk of bias. All three of these studies found a significant reduction in incident delirium after implementation of HELP compared with usual care. Although the findings of the studies were consistent, the average risk of bias was high mainly due to lack of randomization and blinding.

Two studies used proactive geriatric consultation with targeted recommendations based on a structured protocol for patients with hip fracture. One was a single-blind RCT with usual care control,8 while the other was a before-after study with a historical usual care control.9 Both studies reported a significant reduction of incident delirium for the geriatric consult group compared with the usual care group; however, the RCT findings were no longer statistically significant after adjustment for baseline imbalances. The risk of bias was high and moderate for the respective studies.

Of the remaining multicomponent studies, all but one reported a significant reduction in delirium by at least one measure in the intervention group versus the control group. The exception was a study of a system-wide quality improvement project.11 A study of nurse-facilitated family participation reported significantly fewer patients with a diagnosis of delirium (defined by a score ≥4 on the Intensive Care Delirium Screening Checklist [ICDSC]) in the intervention group, but also reported no significant between-group difference in mean scores; this study placed more emphasis on the latter measure.12 Overall, the findings are consistent with the findings from studies of the HELP intervention, although the risk of bias was high again due to lack of randomization and blinding.

#### Long-Term Care

The single study set in a nursing home setting reported that homes randomized to use pharmacist-led geriatric risk assessment medguide (GRAM) reports and automated medication monitoring plans had a significant reduction in potential delirium onset among newly-admitted residents compared with homes randomized to usual care.13 However, it is unclear how much of this is due to delirium prevention or resolution of new-onset delirium.

The majority of the evidence suggests that multicomponent interventions are effective in preventing onset of delirium in at-risk patients. However, these studies do not address the question of which particular components within a program provide the most benefit.

#### Single Interventions

The majority of the single-intervention studies also found a significant reduction in delirium incidence for the study interventions, but roughly one-third (five studies) did not find a significant reduction. Unlike the multicomponent evidence base, almost all of the single-intervention studies were RCTs. However, few studies used the same medication or comparison treatment in the same patient population, making it difficult to determine consistency of findings for most of these interventions.

#### Hospital Inpatient Care

Sedatives/anesthetics. The sedative Dexmedetomidine was compared with other post-operative anesthetics in two studies of patients who underwent cardiac surgery. One found a significant reduction in post-operative delirium for the Dexmedetomidine group compared with patients receiving Propofol or Midazolam.14 This study had a high risk of bias. The other study did not find a significant reduction in post-operative delirium for Dexmedetomidine compared with Morphine, although the study was underpowered to detect a small difference between groups.15 This study did find a significant reduction in duration of delirium for those receiving Dexmedetomidine; the risk of bias was moderate. Because these two studies used different comparison groups, the consistency of the findings cannot be determined.

A study of light versus deep Propofol sedation during spinal anesthesia for hip repair found that patients receiving light Propofol sedation (measured by the bispectral index [BIS]) had a significantly lower rate of postoperative delirium.16 The risk of bias was moderate. It is unclear how this compares to the amount of Propofol used in the study comparing Dexmedetomidine and Propofol, which reported the amount in μg/kg/minute.14

Patients undergoing cardiac surgery had significantly lower rates of postoperative delirium after receiving Ketamine (an NMDA receptor antagonist) during anesthetic induction compared with placebo.17 The risk of bias was moderate, and the findings should be confirmed by other studies.

Patients undergoing joint surgery had significantly lower incidence of delirium after receiving fascia iliac block prophylaxis via Bupivicaine (a local anesthetic) compared with placebo.18 The risk of bias was moderate, and the findings should be confirmed by other studies.

Acetylcholinesterase inhibitors. One study of patients undergoing cardiac surgery did not find a significant between-group difference for those receiving Rivastigmine compared with those receiving placebo.19 This study was judged to have a low risk of bias. Patients undergoing joint surgery who received a different acetylcholinesterase inhibitor (Donepezil) did not show a significant reduction in postoperative delirium compared with those receiving placebo.20 This study had a moderate risk of bias. Pooling of these two studies' findings resulted in a relative risk of 1.11 (95% CI 0.69 to 1.79); the confidence interval was too imprecise to rule out the competing possibilities that acetylcholinesterase inhibitors are ineffective or might confer a benefit.

Atypical antipsychotics. Patients undergoing cardiac surgery had significantly lower rates of postoperative delirium after receiving Risperidone compared with placebo in one RCT with a moderate risk of bias.21 Patients undergoing joint surgery who received Olanzapine had a significant reduction in postoperative delirium compared with placebo in another RCT with low risk of bias.22 Both studies showed a substantial reduction with almost identical risk ratios; the combined summary relative risk is 0.35 (95% CI 0.25 to 0.50, P<0.0001). The findings are therefore consistent and precise for this drug class.

Typical antipsychotics. Patients undergoing joint surgery who received Haloperidol did not show a significant reduction in postoperative delirium compared with those receiving placebo.23 The risk of bias was moderate and the findings were imprecise, therefore requiring confirmation from additional studies.

Melatonin. Patients undergoing joint surgery had significantly lower incidence of delirium after receiving Melatonin compared with placebo.18,22,24 The risk of bias was moderate, and the findings should be confirmed by other studies.

Benzodiazepines. One RCT found that postoperative delirium was significantly lower in gastrointestinal surgery patients who received the benzodiazepines Diazepam + flunitrazepam as a drip infusion in addition to a pethidine drip infusion for the first 3 days compared with those who did not receive these infusions.25 The risk of bias was high.

Music therapy. In two RCTs conducted by the same authors at the same hospital, patients undergoing hip or knee surgery had significantly lower rates of acute confusion after receiving music therapy compared with those receiving usual care.26,27 Both studies had a high risk of bias, in part because they employed an unvalidated delirium assessment method, and should be repeated at other hospitals for confirmation of the results.

#### Long-Term Care

Hydration therapy. A quasi-randomized study comparing 8 weeks of hydration therapy to usual care for delirium prevention among residents of four nursing homes (hydration or control was randomized by nursing home) did not find a significant difference between intervention or control homes in episodes of acute confusion.28 The risk of bias was high.

Acetylcholinesterase inhibitors. A study using Rivastigmine daily for two years in patients with vascular dementia found that the Rivastigmine group had significantly fewer episodes of delirium than those taking cardioaspirin (the control group).29 This was the only study in the entire evidence base that exclusively enrolled patients with dementia, and it was judged to have a high risk of bias. Although these were ambulatory outpatients, they were judged to be similar to patient populations in long-term care settings.

## What Are the Harms of the Patient Safety Practice?

Most trials of delirium prevention programs have not reported any harms. However, it is not clear whether or not the possibility of harms was explicitly assessed in all of these trials. One study of a multicomponent intervention based on a structured quality improvement model reported four unexpected minor events (rectal or feeding tube removal) but no significant complications (and no significant difference compared with usual care).30 Two other multicomponent studies reported no significant differences in complications between intervention and usual care groups.3,13 Seven out of 16 studies on single interventions reported information on adverse events; all seven studies evaluated a variety of medical therapies (medications or anesthesia). Three of these studies reported no significant between-group difference in adverse event rates.16,19,21 One study of Dexmedetomidine versus Morphine for patients after cardiac surgery found that bradycardia occurred significantly more often in the Dexmedetomidine group, while systolic hypotension occurred significantly more often in the Morphine group.15 Another study reported that patients who received Olanzapine had significantly more severe and longer-lasting delirium than patients who received placebo, although incidence of delirium was significantly lower in the Olanzapine group.22 One study of melatonin reported that 2/61 patients had side effects of nightmares or hallucinations, while no patients who received placebo had side effects.24 The remaining study reported no complications associated with fascia iliac block prophylaxis other than local hematomas at the injection site, which resolved spontaneously.18

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

Literature searches identified 15 studies of multicomponent delirium prevention programs that met inclusion criteria (see Table 2). The limited information on how these programs have been implemented and in what contexts is summarized below.

### Structural Organizational Characteristics

Multicomponent delirium prevention programs have been successfully implemented in both acute care hospitals (14 studies) and in nursing homes (1 study). Five of the acute care hospital studies were conducted in the United States, three in the United Kingdom, three in Sweden, and one each in Australia, Spain, and Taiwan. Ten studies were from academically-affiliated urban hospitals, two studies were conducted in urban hospitals that were not described as teaching hospitals, and the remaining two studies were set in community hospitals (in one study the participating community hospitals were part of a larger Health System). No studies have been reported from rural hospitals. The single study of nursing homes was conducted in the U.S..

Existing infrastructure. Only one study reported minimal information on patient safety culture at the organizational level; the authors stated merely that “SHS [Summa Health System] maintains a strong commitment to patient safety and quality.”11

External factors. External factors or motivators were not mentioned in any delirium study.

Implementation. All multicomponent intervention studies provided at least minimal information concerning teamwork and/or leadership at the level of the unit where the intervention was implemented. Eleven of 15 studies specifically identified the study leaders, while 14/15 studies identified the team members by job status (e.g., nurses, geriatricians) or at least stated that all staff in the intervention ward or unit were part of the team. All of these studies reported multidisciplinary teamwork that included clinical experts, nurses, and other staff (e.g., physical therapists, volunteers). One study reported minimal information on teamwork or leadership at the hospital level.11

Seven studies described multi-professional implementation, one had the intervention performed by the ward staff, one involved ward staff plus physical therapists (at home visits), one involved ward staff plus ambulance workers, one involved unit staff plus volunteers, one involved the nursing staff only, one involved nursing staff plus consultant pharmacists, one involved nurses assisting family members with the intervention, and one involved elder life specialists plus volunteers.

Twelve studies reported on staff education/training if this was part of the intervention, and seven studies reported the individual(s) responsible for implementation. Most of these studies reported that all staff involved in the implementation underwent some type of education or training. Ten studies reported the type of training, and only four studies reported the length of training.

Four studies reported a change in the implementation process due to local tailoring or an iterative process. Only one study (Rubin et al. 2011) reported that internal incentives were used to promote implementation.5 Allen et al. (2011) published the only study that provided a table summarizing an actual implementation instrument (a scorecard used to track process and outcome variables).11

Fourteen studies outlined the intended intervention and the general sequence in which the components were implemented; only 11 studies included enough detail to determine the roles of the various team members. However, this was generally a description of how the intervention was supposed to be implemented; most studies did not describe any modifications or failures of adherence that might have occurred during the actual implementation. Only one study actually measured adherence to targeted recommendations, reporting an adherence rate of 77% regarding implementation of a geriatric consultant's recommendations for patients after hip fracture repair.8 Twelve studies reported patient characteristics.

Although implementation of multicomponent delirium prevention programs has not been well-described in most studies, a few themes seem sufficiently constant to report here:

- Engagement of front line clinical staff in the design of the intervention helps ensure that it will mesh with existing clinical procedures.
- A multidisciplinary team comprising clinical experts, nurses and additional staff is helpful for implementation of a complex intervention
- Education and training of clinical staff is necessary to help ensure compliance does not fall.

## Are There Any Data About Costs?

Two studies in the evidence base reported information on costs or cost savings associated with multicomponent delirium prevention programs. Rizzo et al. calculated the total intervention costs of HELP over a three year period (1995-1998) at Yale-New Haven hospital as $257,385 (personnel plus equipment costs). In a cost-effectiveness analysis, they found that the intervention was cost-effective for patients at intermediate risk of delirium but not for patients at high risk of delirium (lack of effectiveness and higher overall costs). However, these findings may be due to inadequate power based on their sample size of higher risk patients.31 Rubin et al. calculated that implementation of HELP at their hospital led to estimated cost savings of over $2 million per year from prevention of delirium cases. In addition, there was over $2.2 million per year of estimated revenue generated by shorter hospital stays for patients without delirium.5

## What Is Known About the Effect of Context on Outcomes?

Only two studies reported on the effect of context on outcomes. One study of an educational package for medical and nursing staff reported that it was effective at preventing delirium in hospitalized men but not in women.32,33 A study of proactive geriatric consultation with target recommendations based on a structured protocol for patients with hip fracture reported a “trend” toward more effectiveness among patients without pre-fracture dementia or activities of daily living (ADL) impairment, but the differences were not statistically significant.8

One study assessed the somewhat related concept of patient adherence and its effect on outcomes of a multifactorial intervention (HELP). Based on a composite adherence score for the three components assigned to all patients (orientation, mobility, and therapeutic activities), increased adherence scores were associated with a reduction in delirium incidence rates (OR 0.69, 95% CI 0.56 to 0.87).7

## Conclusions and Comment

Evidence from multiple studies suggests that a variety of factors may contribute to a hospital patient's risk for developing delirium; cognitive deficit was most consistently shown to be a risk factor in these studies. All but two studies were judged to have high risk of bias, and these exceptions were judged to have a moderate risk of bias. The majority of the evidence suggests that most multicomponent interventions are effective in preventing onset of delirium in at-risk patients in a hospital setting (Strength of Evidence: Moderate). In general, successful delirium prevention programs involved a multidisciplinary team of clinical experts, nurses, and other staff (e.g., physical therapists, volunteers) and included protocols for early mobilization of patients, volume repletion (for hydration and electrolyte balance), and addressing visual or hearing deficits; a few programs included elimination of unnecessary medications.

Other components reported in more than one study included staff education, geriatric consultation, therapeutic cognitive activities/orientation, extra nutrition, sleep enhancement, pain management, anesthetic protocols, supplemental oxygen, assessment of bowel/bladder functions, and prevention and treatment of medical complications. However, these studies do not address the question of which particular components within a program provide the most benefit.

There was not enough evidence to evaluate the benefit of delirium prevention programs in long-term care settings.

Although implementation of multicomponent delirium prevention programs has not been well-described in most studies, a few themes seem sufficiently constant to report here:

- Engagement of front line clinical staff in the design of the intervention helps ensure that it will mesh with existing clinical procedures.
- A multidisciplinary team comprising clinical experts, nurses and additional staff is helpful for implementation of a complex intervention
- Education and training of clinical staff is necessary to help ensure compliance does not fall.

Although several of the single-intervention studies also found a significant reduction in delirium incidence for the study interventions, few studies used the same medication or comparison treatment in the same patient population; this makes it difficult to determine consistency of findings for most of these interventions. For atypical antipsychotics, two RCTs with a low to moderate risk of bias evaluating different drugs within this class showed consistent and precise findings of reduction in postoperative delirium among surgical patients (Strength of Evidence: Moderate). Although two RCTs reported a significant reduction in acute confusion for patients receiving music therapy, these studies were conducted at the same institution by the same authors and used an unvalidated delirium assessment method. Therefore, the evidence is insufficient for a conclusion regarding music therapy. Two RCTs had inconclusive findings (even when pooled) regarding the efficacy of acetylcholinesterase inhibitors, rendering the strength of evidence insufficient.

Most of the remaining treatments (or treatment comparisons) were represented by only one study with a moderate or high risk of bias; we judged the evidence about these treatments to be insufficient.

Future comparative effectiveness studies with standardized protocols are needed, particularly to identify which components in multicomponent interventions are most effective for delirium prevention. Identification of the most effective bundle of components might encourage hospitals to adopt a more standardized approach to delirium prevention. Additional RCTs are also needed to determine which single-component medical therapies or drug classes are truly beneficial for patients at risk of delirium. A summary table is located below (Table 1).

Table 1, Chapter 20 Summary table

Scope of the Problem targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Low | Moderate | Low | Moderate | Moderate/Moderate

## References

1 Leslie DL, Marcantonio ER, Zhang Y, et al. One-year health care costs associated with delirium in the elderly population. Arch Intern Med. Jan. 14. 2008;168(1):27-32. [pmid: 18195192].
2 Rudolph JL, Marcantonio ER. Postoperative Delirium: acute change with long-term implications. Anesth Analg. May. 2011;112(5):1202-11. [pmid: 21474660].
3 Bjorkelund KB, Hommel A, Thorngren KG, et al. Reducing delirium in elderly patients with hip fracture: a multi-factorial intervention study. Acta Anaesthesiol Scand. Jul. 2010;54(6):678-88. [pmid: 20236093].
4 Lundstrom M, Olofsson B, Stenvall M, et al. Postoperative delirium in old patients with femoral neck fracture: a randomized intervention study. Aging Clin Exp Res. Jun. 2007;19(3):178-86. [pmid: 17607084].
5 Rubin FH, Neal K, Fenlon K, et al. Sustainability and scalability of the hospital elder life program at a community hospital. J Am Geriatr Soc. Feb. 2011;59(2):359-65. [pmid: 21314654].
6 Chen CC, Lin MT, Tien YW, et al. Modified hospital elder life program: effects on abdominal surgery patients. J Am Coll Surg. Aug. 2011;213(2):245-52. [pmid: 21641835].
7 Inouye SK, Bogardus ST Jr, Williams CS, et al. The role of adherence on the effectiveness of nonpharmacologic interventions: evidence from the delirium prevention trial. Arch Intern Med. Apr. 28. 2003;163(8):958-64. [pmid: 12719206].
8 Marcantonio ER, Flacker JM, Wright RJ, et al. Reducing delirium after hip fracture: a randomized trial. J Am Geriatr Soc. May. 2001;49(5):516-22. [pmid: 11380742].
9 Wong DM, Niam T, Bruce JJ, et al. Quality project to prevent delirium after hip fracture. Aust J Ageing. 2005;24(3):174-7.
10 Inouye SK, Bogardus ST Jr, Charpentier PA, et al. A multicomponent intervention to prevent delirium in hospitalized older patients. N Engl J Med. Mar. 4. 1999;340(9):669-76. [pmid: 10053175].
11 Allen KR, Fosnight SM, Wilford R, et al. Implementation of a system-wide quality improvement project to prevent delirium in hospitalized patients. J Clin Outcomes Manag. Jun. 2011;18(6):253-8.
12 Black P, Boore JR, Parahoo K. The effect of nurse-facilitated family participation in the psychological care of the critically ill patient. J Adv Nurs. May. 2011;67(5):1091-101. [pmid: 21214624].
13 Lapane KL, Hughes CM, Daiello LA, et al. Effect of a pharmacist-led multicomponent intervention focusing on the medication monitoring phase to prevent potential adverse drug events in nursing homes. J Am Geriatr Soc. Jul. 2011;59(7):1238-45. [pmid: 21649623].
14 Maldonado JR, Wysong A, van der Starre PJ, et al. Dexmedetomidine and the reduction of postoperative delirium after cardiac surgery. Psychosomatics. May-Jun. 2009;50(3):206-17. [pmid: 19567759].
15 Shehabi Y, Grant P, Wolfenden H, et al. Prevalence of delirium with dexmedetomidine compared with morphine based therapy after cardiac surgery: a randomized controlled trial (DEXmedetomidine COmpared to Morphine-DEXCOM Study). Anesthesiology. Nov. 2009;111(5):1075-84. [pmid: 19786862].
16 Sieber FE, Zakriya KJ, Gottschalk A, et al. Sedation depth during spinal anesthesia and the development of postoperative delirium in elderly patients undergoing hip fracture repair. [Erratum appears in Mayo Clin Proc. 2010 Apr;85(4):400 Note: Dosage error in article text. Mayo Clin Proc. Jan. 2010;85(1):18-26. [pmid: 20042557].
17 Hudetz JA, Patterson KM, Iqbal Z, et al. Ketamine attenuates delirium after cardiac surgery with cardiopulmonary bypass. J Cardiothorac Vasc Anesth. Oct. 2009;23(5):651-7. [pmid: 19231245].
18 Mouzopoulos G, Vasiliadis G, Lasanianos N, et al. Fascia iliaca block prophylaxis for hip fracture patients at risk for delirium: a randomized placebo-controlled study. J Orthop Traumatol. 2009;10(3):127-33. [pmid: 19690943].
19 Gamberini M, Bolliger D, Lurati Buse GA, et al. Rivastigmine for the prevention of postoperative delirium in elderly patients undergoing elective cardiac surgery--a randomized controlled trial. Crit Care Med. May. 2009;37(5):1762-8. [pmid: 19325490].
20 Liptzin B, Laki A, Garb JL, et al. Donepezil in the prevention and treatment of post-surgical delirium. Am J Geriatr Psychiatry. Dec. 2005;13(12):1100-6. [pmid: 16319303].
21 Prakanrattana U, Prapaitrakool S. Efficacy of risperidone for prevention of postoperative delirium in cardiac surgery. Anaesth Intensive Care. Oct. 2007;35(5):714-9. [pmid: 17933157].
22 Larsen KA, Kelly SE, Stern TA, et al. Administration of olanzapine to prevent postoperative delirium in elderly joint-replacement patients: a randomized, controlled trial. Psychosomatics. Sep-Oct. 2010;51(5):409-18. [pmid: 20833940].
23 Kalisvaart KJ, de Jonghe JF, Bogaards MJ, et al. Haloperidol prophylaxis for elderly hip-surgery patients at risk for delirium: a randomized placebo-controlled study. J Am Geriatr Soc. Oct. 2005;53(10):1658-66. [pmid: 16181163].
24 Al-Aama T, Brymer C, Gutmanis I, et al. Melatonin decreases delirium in elderly patients: a randomized, placebo-controlled trial. Int J Geriatr Psychiatry. Jul. 2011;26(7):687-94. [pmid: 20845391].
25 Aizawa K, Kanai T, Saikawa Y, et al. A novel approach to the prevention of postoperative delirium in the elderly after gastrointestinal surgery. Surg Today. 2002;32(4):310-4. [pmid: 12027195].
26 McCaffrey R, Locsin R. The effect of music on pain and acute confusion in older adults undergoing hip and knee surgery. Holist Nurs Pract. Sep-Oct. 2006;20(5):218-24. quiz 225-6. [pmid: 16974175].
27 McCaffrey R, Locsin R. The effect of music listening on acute confusion and delirium in elders undergoing elective hip and knee surgery. J Clin Nurs. 2004;13(s2):91. [pmid: 15724823].
28 Mentes JC, Culp K. Reducing hydration-linked events in nursing home residents. Clin Nurs Res. Aug. 2003;12(3):210-25. discussion 226-8. [pmid: 12918647].
29 Moretti R, Torre P, Antonello RM, et al. Cholinesterase inhibition as a possible therapy for delirium in vascular dementia: a controlled, open 24-month study of 246 patients. Am J Alzheimers Dis Other Demen. Nov-Dec. 2004;19(6):333-9. [pmid: 15633941].
30 Needham DM, Korupolu R, Zanni JM, et al. Early physical medicine and rehabilitation for patients with acute respiratory failure: a quality improvement project. Arch Phys Med Rehabil. Apr. 2010;91(4):536-42. [pmid: 20382284].
31 Rizzo JA, Bogardus ST Jr, Leo-Summers L, et al. Multicomponent targeted intervention to prevent delirium in hospitalized older patients: what is the economic value. Med Care. Jul. 2001;39(7):740-52. [pmid: 11458138].
32 Tabet N, Hudson S, Sweeney V, et al. An educational intervention can prevent delirium on acute medical wards. Age Ageing. Mar. 2005;34(2):152-6. [pmid: 15713859].
33 Tabet N, Stewart R, Hudson S, et al. Male gender influences response to an educational package for delirium prevention among older people: a stratified analysis. Int J Geriatr Psychiatry. May. 2006;21(5):493-7. [pmid: 16676296].