# Prevention of Central Line-Associated Bloodstream Infections: Brief Update Review

## Introduction

Central venous catheters (CVCs) are intravascular access devices that terminate within the great vessels of the neck (superior or inferior vena cava, brachiocephalic veins, subclavian vein or internal jugular vein), or a site proximal to the heart. CVCs are vital for the care of hospitalized and critically ill patients, as they provide reliable venous access for clinical activities such as blood sampling, infusion of medications, and hemodynamic measurement. However, CVCs are also the leading cause of healthcare-associated bloodstream infections (BSIs) and are frequently implicated in life-threatening illnesses.1,2 Infections associated with CVCs are categorized in the literature as either “central-line associated bloodstream infection” (CLABSI), or “catheter-related bloodstream infection” (CRBSI), based on whether surveillance or ascertainment of infection is the desired goal. For instance, the Centers for Disease Control and Preventions' (CDC) National Healthcare Safety Network (NHSN) uses the CLABSI definition for surveillance purposes, defining the term as a laboratory confirmed BSI in any patient with a CVC present either at the time of, or within a 48-hour period before the detection of infection.3,4 Thus, the CDC-NSHN definition overestimates the true incidence of CRBSI, as some BSIs may be due to infection at other sites (e.g., pneumonia or urinary tract infection) or at sites that are difficult to detect (e.g., translocation from the gastrointestinal tract or mucositis following chemotherapy). In contrast, CRBSI is a more precise and rigorous definition that requires either (a) isolation of the same organism from the catheter and the peripheral blood, (b) simultaneous quantitative blood cultures with a ratio of 5:1 or higher of those from the indwelling CVC compared with peripheral blood, or (c) a differential time to positivity of CVC-derived versus (vs.) peripheral blood culture positivity of more than 2 hours.5 The CRBSI definition is thus largely used within the context of clinical care and research, whereas the term, CLABSI, is implemented for epidemiologic surveillance.6 For the purposes of this review, we use the term CLABSI to encompass both of these operational definitions.

Of the approximately 249,000 BSIs that occur in U.S. hospitals each year, 80,000 (32.2%) occur in intensive care unit (ICU) settings.2 Because CVCs are more frequently used in ICUs than in other areas of the hospital, and the strongest predictor of developing a BSI is the presence of a CVC, the epidemiology of CLABSI has traditionally focused on the critically ill. With over 15 million catheter days in ICUs annually, the potential impact of CLABSI is substantial in this population alone.6,7 However, in a survey of major medical centers, CVC use was identified in 24.4 percent of patients outside the ICU.8 Thus, millions of patients both in and out of ICU settings are potentially at risk of developing CLABSI. Although the frequency of CLABSI outside the ICU is largely unknown, Weber and colleagues found that the incidence of CLABSI decreased when patients transitioned from ICUs to step-down units or non-ICU floors.9 Data from the CDC-NHSN also suggest lower CLABSI rates in patients on hospital wards compared with those in an ICU setting.10 Furthermore, recent evidence suggests that the incidence of CLABSI in ICUs is significantly lesser than reported in 2001, likely due to a number of efforts aimed at preventing this infection.11 These efforts notwithstanding, the increasing use of CVCs such as peripherally inserted central catheters (PICCs) outside of ICUs may reflect an important shift in the epidemiology of CLABSI to non-ICU settings.12 This change is highly relevant, as lack of a uniform patient-care team and absence of comprehensive surveillance efforts in non-ICU settings represent substantial obstacles to addressing CLABSI in these areas.

The economic burden of CLABSI is substantial. A recent analysis estimated that each CLABSI episode independently increases length of hospitalization from 7 to 21 days, and adds an attributable cost of about $37,000 (2002 dollars) per patient.13 The annual national cost of caring for patients who develop CLABSI is estimated to range from $0.67 to $2.68 billion.13-15 Similar trends exist in European nations, where the incremental expenditure related to CLABSI is estimated at €9,154 (€18,241 [$24,558 in 2012 dollars vs. €9,087 [$12233]) per patient.16 Given this clinical and economic cost, investigators, policy-makers, and regulatory agencies in the U.S. and abroad have devoted great efforts to curtail CLABSI over the past decade.17-19

CLABSIs are potentially preventable through the use of evidence-based practices.20 The original “Making Health Care Safer” report examined the prevalence, strategies, and costs associated with CLABSI prevention, and found that certain practices (e.g., the use of maximal sterile precautions) were associated with both a decrease in CLABSI risk and reduced cost, whereas others (e.g., intravenous antimicrobial prophylaxis) added expense without clear benefit.21,22 In this review, we provide an update to the original report by highlighting the most clinically and cost effective strategies associated with CLABSI prevention. To compile this report, we performed a systematic review of the literature and searched multiple databases to identify relevant studies published between 2000 and 2012 using terms such as “Bacteremia,” “Catheterization, Central Venous,” and “central line-associated bloodstream infection.” Our search strategy yielded a total of 1,087 unique manuscripts of which 337 articles were relevant for this report.

## What Practices Are Associated With CLABSI Prevention?

One of the most important advances in the science of CLABSI prevention has been the identification of individual risk factors associated with this condition. These include (a) lengthy hospitalization before venous catheterization; (b) prolonged duration of catheterization; (c) heavy microbial colonization at the insertion site; (d) heavy microbial colonization of the catheter hub; (e) femoral or internal jugular vein insertion (rather than subclavian vein); (f) operator-inexperience or lack of implementation of best practices during CVC insertion; (g) presence of neutropenia; (h) total parenteral nutrition provided through the catheter; (i) inadequate care/maintenance of the CVC after insertion; and (j) type of CVC.23-30 Strategies to prevent CLABSI have evolved from targeting these variables.

The CD's Healthcare Infection Control Practices Advisory Committee (HICPAC) recently updated their guidelines to summarize the evidence behind a number of practices associated with CLABSI reduction.20 As with prior iterations, the update provides levels of recommendation for each clinical practice based on the theoretical rationale, scientific data, applicability and impact of the intervention. Based on the level of evidence in their support, recommendations are divided into five categories, ranging from practices that are strongly recommended and supported by well-designed experimental, clinical, or epidemiologic studies to those that are of unclear value owing to insufficient evidence or lack of consensus regarding efficacy (Table 1). From a conceptual standpoint, these practices can be classified as (a) interventions that may be implemented at the time of CVC insertion; (b) practices best utilized after placement of a CVC; and (c) institutional initiatives to reduce CLABSI.

Table 1, Chapter 10 Categories and recommendations for CLABSI reduction practices from the Healthcare Infection Control Practices Advisory Committee of the Centers for Disease Control and Prevention^*^

Recommendation | Description | Category of Recommendation
Hand hygiene prior to catheter insertion | Decontaminate hands with either antiseptic-containing soaps or alcohol-based gels/foams before inserting, repairing, replacing, or dressing a CVC | Category IB
All inclusive catheter carts or kits | A catheter kit or cart contains all the equipment necessary for CVC insertion (needle, guidewire, introducers, etc.), and ensures sterility by minimzing interruptions during line placement | Category IB
Maximal sterile barrier precautions | Use a cap, mask, sterile gown, sterile gloves, and a sterile full body drape when inserting CVCs and PICCs or performing guidewire exchange(s) | Category IB
Chlorhexidine for skin anti-sepsis | Prepare clean skin with chlorhexidine preparation with alcohol before CVC insertion and during dressing changes | Category IA
Antimicrobial catheters | Chlorhexidine/silver sulfadiazine or minocycline/rifampin-impregnated CVCs are recommended only if the catheter is expected to remain in place 5 days or more [underlined: AND] the CVC will be inserted in an environment where the CLABSI rate remains high despite a comprehensive reduction strategy | Category IA
Subclavian vein insertion | Whenever possible, use the subclavian site, rather than the jugular or femoral sites in adults | Category IB
Disinfect hubs and needle-less connectors | Minimize contamination risk by scrubbing the access site with an appropriate antiseptic (chlorhexidine, povidone iodine, or 70% alcohol) prior to accessing the CVC | Category IA
Remove non-essential CVCs | Daily evaluation and prompt removal of CVCs that are no longer clinically warranted is an important aspect of CLABSI prevention; routine replacement of CVCs, PICCs, or hemodialysis catheters is not recommended | Category IA
Chlorhexidine cleansing | Daily cleansing using a 2% chlorhexidine solution or impregnated washcloth rather than soap and water in ICU- and hemodialysis patients is recommended | Category II
CVC dressing | Use either sterile gauze or sterile, transparent, semipermeable dressing to cover the CVC site | Category IA
Chlorhexidine sponge dressing | The use of chlorhexidine-impregnated sponge dressings is recommended for patients ≥2 months of age if the CLABSI rate is not decreasing despite adherence to basic prevention measures, including education and training, appropriate use of chlorhexidine for skin antisepsis and use of maximal sterile barrier precautions | Category 1B
Topical antibiotic use | Topical antibiotic use may promote fungemia or bacteremia in non-dialysis populations and is recommended only for hemodialysis catheter dressing | Category IB
Antibiotic or anti-infective “locks” | Instillation of supra-physiologic doses of an intravenous antibiotic or anti-infective solution into a catheter lumen between periods of CVC access is recommended only in those at high baseline risk for CLABSI | Category II
Systemic antibiotic prophylaxis | The use of oral or intravenous antibiotic therapy either during insertion or following placement of a CVC is not recommended | Category IB
Educational interventions | Education regarding appropriate indications, method of placement, and surveillance for CLABSI are a critical component of a comprehensive CLABSI prevention program | Category IA
Catheter bundles or “checklists” | The use of five practices in unison at the time of CVC insertion, “the bundle,” is recommended. These interventions include hand hygiene prior to insertion; use of maximal sterile barrier precautions; chlorhexidine for skin antisepsis; avoidance of the femoral site of insertion; and prompt removal of catheters when no longer indicated | Category IB
Use of specialized CVC insertion teams | The use of trained personnel dedicated to the placement of CVCs in ICU and hospitalized patients is recommended | Category IA

* Categories of recommendations:

- Category IA: Strongly recommended for implementation and strongly supported by well-designed experimental, clinical, or epidemiologic studies;
- Category IB: Strongly recommended for implementation and supported by some experimental, clinical, or epidemiologic studies and a strong theoretical rationale; or an accepted practice (e.g., aseptic technique) supported by limited evidence.
- Category IC: Required by State or Federal regulations, rules, or standards.
- Category II: Suggested for implementation and supported by suggestive clinical or epidemiologic studies or a theoretical rationale.
- Unresolved Issue: No specific recommendations exist due to conflicting or insufficient evidence.

Abbreviations: CLABSI = central line-associated bloodstream infection; CVC = central venous catheter; PICC = peripherally inserted central catheter.

Note: Adapted from O'Grady, et al.20

### Measures To Prevent CLABSI at Time of Central Venous Catheter Insertion

Hand hygiene before catheter insertion. Hand hygiene is an important practice in the prevention of CLABSI.31 Hand decontamination with either antiseptic-containing soaps or alcohol-based gels/foams has consistently been shown to reduce CLABSI rates.32-34 A key strategy in promoting hand hygiene involves educating staff who insert CVCs on the importance of this practice. In a before-and-after study assessing the impact of an educational initiative on hand hygiene, the incidence of CLABSI decreased from 3.9 per 1,000 catheter days to 1.0 per 1,000 catheter days (P< 0.001) following education on this topic in an ICU setting.35 As the most common cause of CLABSI is entry of skin pathogens during CVC insertion and maintenance, ensuring best practice during catheter placement and handling is crucial for CLABSI prevention (Category IB).20,36

All-inclusive catheter-carts or kits. A study by Young and colleagues found that a systems-based intervention featuring a catheter kit (that contained a large sterile drape and 2% chlorhexidine gluconate) led to a significant reduction in CLABSI rates (11.3 per 1,000 CVC-days vs. 3.7 per 1000 CVCs, P<0.01) in a medical-surgical ICU.37 This approach has been expanded upon by a number of other investigators to include not only a kit of essential items, but a mobile cart that contains all of the equipment needed to insert CVCs.38,39 The use of an all-inclusive cart or catheter kit minimizes interruptions related to non-availability of necessary equipment and thus lends itself to CLABSI reduction by ensuring maintenance of a sterile field during catheter insertion. Furthermore, the use of carts encourages a consistent approach to CVC insertion by standardizing catheter types, guide-wires, needles, and other essential supplies. Although the use of catheter-carts and kits is not specifically endorsed by the recent HICPAC guidelines,20 they are pragmatic, relatively low-cost innovations that have been associated with lower CLABSI rates.

Maximal sterile barrier precautions. Several studies have demonstrated that the use of maximal barrier precautions including a cap, mask, sterile gown, gloves, and a sterile full-body drape when inserting CVCs reduces CLABSI.6,37,40,41 Current HICPAC guidelines thus recommend that maximal sterile barriers are used during insertion of all CVCs (Category IB).20 The cost-effectiveness of this practice in preventing CLABSI has been established, as the expense of sterile barriers is dwarfed by the additional expense of CLABSI and its subsequent care, even in resource-poor environments.42 Despite this evidence, a study of 10 ICUs in major academic medical centers published in 2006 reported that fewer than 30 percent had systematically adopted maximal sterile barrier precautions.43 However, a more recent national survey of infection preventionists, which examined the use of evidence-based practices (including maximal sterile barriers) in Federal and non-Federal hospitals between 2005 and 2009, found that the reported use of this practice is on the rise.44 This more recent finding highlights the fundamental role of translating evidence into practice regarding CLABSI prevention.

Chlorhexidine for skin antisepsis. In a systematic review and meta-analysis of 8 trials involving 4,143 unique catheter insertions, skin antisepsis with chlorhexidine was found to be associated with a 50 percent reduction in the subsequent risk of CLABSI compared with povidone iodine.45 A formal economic evaluation by the same authors projected that although costlier initially, the use of chlorhexidine over povidone iodine for insertion site disinfection and CVC care would lead to a 1.6 percent decrease in the incidence of CLABSI, a 0.23 percent decrease in the incidence of death, and a savings of $113 per catheter.46 Existing HICPAC guidelines endorse the use of chlorhexidine gluconate for skin antisepsis prior to CVC insertion (Category IA).20

Antimicrobial catheters. The utility of catheters impregnated with a variety of substances including chlorhexidine-silver sulfadiazine, minocycline-rifampin, benzalkonium chloride, and silver have been evaluated in more than 20 randomized controlled studies and four recent systematic reviews and meta-analyses.47-51 Meta-conclusions from these reviews remain limited, due to heterogeneity arising from differences in the population, design, and conduct of the pooled studies. For example, in a study involving a pediatric burn population, Weber and colleagues found significant reductions in CLABSI with the use of minocycline and rifampin antimicrobial coated catheters over non-coated catheters.52 However, a prospective, double-blinded, randomized study in adults failed to show a reduction in CLABSI with a second-generation CVC coated with chlorhexidine and silver sulfadiazine.53 Due to the initial acquisition cost, variation in benefit according to patient populations, and potential concern for inducing antimicrobial resistance, routine use of antimicrobial CVCs is not recommended.20,54 However, in facilities where high-rates of CLABSI persist despite deployment and compliance with comprehensive CLABSI prevention efforts, the use of antimicrobial CVCs is considered reasonable by current HICPAC guidelines (Category IA).20

The subclavian vein as the insertion point of choice. The site of CVC placement may influence the risk of CLABSI, owing to the differing density of bacterial skin colonization at each entry site. In a multicenter study of 289 patients randomized to undergo venous catheterization using either the femoral or subclavian site, CVC placement in the femoral area was associated with a substantially greater risk of CLABSI than was subclavian insertion (20 versus 3.7 per 1,000 catheter days).55 In a recent Dutch multicenter study involving 3,750 CVCs and 29,003 CVC days, insertion into the femoral and jugular vein was independently associated with an increase in the risk of subsequent CLABSI.56 In a study directly comparing the subclavian to the internal jugular and femoral sites, the subclavian site was associated with the lowest risk of infection (0.97 versus 2.99 and 8.34 per 1,000 catheter days, respectively).24 For this reason, whenever medically feasible, the subclavian vein is the preferred site for venous catheterization in the current HICPAC guidelines (Category IB).6,20,57-59 However, this recommendation remains the subject of ongoing debate, as some rigorous studies have found that the risk of CLABSI from femoral vein CVC insertion is not greater than that associated with insertion into the subclavian or internal jugular veins.60-62

### Measures To Prevent CLABSI After Central Venous Catheter Insertion

Following the insertion of a CVC, several practices may decrease the risk of developing CLABSI. These “maintenance” practices are important aspects of CLABSI prevention, especially in CVCs that remain in place for an extended period of time.

Disinfect hubs, needleless connectors, and injection ports prior to CVC use. Contamination of the catheter hub due to non-sterile access technique is a recognized path for developing CLABSI. Minimizing contamination by wiping the catheter hub with an appropriate antiseptic specifically recommended by the device manufacturer, or swabbing the membranous septum of a CVC with 70% alcohol have been shown to reduce both risk of catheter contamination and incidence of CLABSI.63-65 The practice of disinfecting access sites prior to CVC use, colloquially dubbed “scrub the hub,” is linked to decreases in both bacterial colonization at access sites and rates of incident CLABSI.66-68 Educational efforts targeting providers responsible for CVC care (such as bedside nurses) are an important component in ensuring dissemination and compliance with this practice.69 Although current HICPAC guidelines emphasize minimizing the risk of contamination by scrubbing the hub with an appropriate antiseptic (Category IA),20 several in vitro studies have demonstrated that even with strict attention to decontamination, pathogenic organisms can persist in crevices or inside CVC access valves and/or require prolonged duration of contact with an antimicrobial to significantly decrease the level of colonization of CVC valves.69-72 In response, innovative technologies such as those that incorporate antimicrobial compounds in the matrix of the CVC access valve, or devices that bathe the valve with antimicrobials are being developed and tested.70,72-74 In the absence of significant clinical experience with these novel devices, recommendations regarding their widespread use are not possible.

Remove nonessential CVCs. Each day with a CVC increases the risk of developing CLABSI.75,76 Prompt removal of CVCs that are no longer warranted is thus an important practice to reduce CLABSI. This action necessitates both awareness of CVC presence and an ongoing risk-benefit assessment of continued central venous access. In a study tracking temporary CVC use in hospitalized patients, Chernetsky-Tejedor and colleagues reported that patients who underwent PICC placement for venous access paradoxically also had 5.4 concurrent days with a peripheral intravenous line (P<0.001), and had more days in which the only justification for the CVC was intravenous administration of antimicrobial agents (8.5 versus 1.6 days; P=0.0013). The authors therefore concluded that a substantial proportion of CVC-days might have been unjustified in this cohort.65 In a recent survey conducted in a European hospital, neither the bedside nurse nor the treating physician knew why a CVC was in place for 8.3 percent of non-ICU patients.77 Importantly and relatedly, routine replacement of CVCs at pre-determined time intervals has not been shown to reduce the risk of CLABSI and is not recommended based on the available evidence (Category IA).20

Chlorhexidine cleansing. Daily bathing of patients with a chlorhexidine-based solution in ICU- or advanced care settings may lower CLABSI incidence. In a crossover study conducted in a medical ICU, daily washing with a 2% chlorhexidine-impregnated washcloth significantly reduced subsequent BSI compared with using soap and water (4.1 vs. 10.4 per 1,000 patient-days, P<0.05).78 A study in a surgical ICU also found that daily bathing with a 2% chlorhexidine gluconate impregnated cloth led to significant reductions in CLABSI (12.07 vs. 3.17 CLABSIs per 1,000 days; 73.7% rate reduction, P= 0.04).79 The benefits of chlorhexidine baths may also extend to high-risk patients outside of ICU settings. In a quasi-experimental before and after study of the effect of daily washing with 2% chlorhexidine solution on CLABSI incidence, Munoz-Price and colleagues reported a 99 percent reduction in the CLABSI rate in a long-term acute care facility.80 However, a recent retrospective study involving patients in a surgical ICU suggested that the benefit from chlorhexidine bathing might not apply to all patients.81 As the evidence base for this practice is limited and conflicting, current HICPAC guidelines cautiously endorse the use of chlorhexidine washes (either in solution form or as a chlorhexidine impregnated wash cloth), for daily skin cleansing as a means to prevent CLABSI with a Category II recommendation.20 However, the level of evidence for this recommendation may soon be upgraded, as a recent meta-analysis pooling 12 studies found significant reductions in CLABSI risk in studies that evaluated chlorhexidine cleansing in a medical ICU setting (OR 0.44, 95% confidence interval, 0.33 to 0.59).82

CVC dressing, chlorhexidine sponges and topical antibiotic use. The type of dressing and use of topical antibiotic ointments or creams at the catheter site may affect the risk of CLABSI. In a meta-analysis of seven studies comparing clear dressings to gauze for CVCs, transparent dressings were associated with greater risk of catheter tip colonization (Relative Risk [RR] 1.78, 95% confidence interval [CI] 1.30 to 2.30, P<0.05), but not CLABSI (RR 1.63, 95% CI 0.76 to 3.47).83 Another meta-analysis of randomized controlled trials comparing gauze and tape to transparent dressings found no significant differences between dressing type and risk of CLABSI.84 Thus, for CLABSI prevention, existing guidelines do not endorse one type of dressing over the other and leave the choice of CVC dressing to provider/patient preference and clinical scenario.20

The use of a chlorhexidine gluconate sponge over the site of CVC insertion has been associated with a decrease in the frequency and cost of CLABSI. In a study involving 1,636 patients with venous and arterial catheters, Timsit and colleagues reported that chlorhexidine gluconate sponge placement at the site of catheter insertion substantially reduced the incidence of CLABSI (1.4 to 0.6 per 1,000 catheter days, hazard ratio 0.39, P<0.03). However, severe contact dermatitis was observed in eight low birth-weight infants (5.3 per 1,000 catheter days), and the potential for this adverse effect remains an important limitation in the use of chlorhexidine gluconate sponges in this population.85 In a recent economic evaluation, chlorhexidine-impregnated sponge use in patients with CLABSI was estimated to save $197 per patient using a 3-day dressing change strategy vs. $83 using a 7-day standard dressing change strategy.86 In another cost-benefit analysis, a hypothetical 400-bed hospital inserting 3,078 CVCs annually would avoid a projected average of 35 CLABSIs, 145 local infections, and 281 ICU days with the systematic use of a chlorhexidine-impregnated foam dressing; potential annual hospital net savings were projected at over $895,000.^87^ Owing to important differences in study design and outcomes involving primarily pediatric populations, current guidelines recommend the use of chlorhexidine-impregnated sponge dressings only in situations where the CLABSI rate is not decreasing despite adherence to other prevention measures (Category IB).20

The use of topical antibiotic ointment or creams at the insertion site (e.g. povidone iodine) is recommended only for patients with hemodialysis catheters, where its use has been associated with suppression of BSI.88,89 Interestingly, a recent prospective, non-blinded crossover study found that chlorhexidine sponge dressings were not protective against BSI in patients with hemodialysis catheters.90 Conversely, topical antibiotic dressings are not recommended for CLABSI prevention in non-dialysis patients as their use may paradoxically increase fungemia and antimicrobial resistance in this category of patients (Category IB).20,91,92

Antibiotic/anti-infective “locks” in high-risk patients. A catheter lock refers to the instillation of supra-physiologic doses of an intravenous antibiotic or anti-infective solution into a catheter lumen between periods of CVC access. Several studies have examined both the utility of specific antibiotic or anti-infective agents (e.g. vancomycin, cephalosporins, taurolidine, EDTA, ethanol) and the targeted use of antibiotic locks in high-risk patient populations. In a systematic review and meta-analysis, vancomycin-based antibiotic locks in patients deemed high-risk for CLABSI (planned, long-term central venous catheter duration or those with a history of prior CLABSI) significantly decreased the risk of this outcome (RR 0.34, P=0.04).93 A more recent systematic review also reported reductions in the risk of subsequent CLABSI using this approach as an adjunctive treatment, specifically in patients with poor venous access where catheter salvage was key.94 In view of concerns regarding the potential for inducing antibiotic resistance, several novel compounds have been tested as anti-infective locks. For example, a recent study found a solution containing minocycline and EDTA to be highly efficacious in preventing CLABSI in patients with hemodialysis catheters.95 In patients receiving prolonged home parenteral nutrition via a CVC, the antineoplastic compound taurolidine was found to reduce the risk of CLABSI when used as a catheter lock in a before and after study.96 Even though several studies have found reductions in CLABSI incidence in specific populations, generalizations beyond these groups are difficult and not appropriate.97-100 Thus, due to important differences in study design, type of catheter, agent used, and patient population, the use of antibiotic locks should be limited to those who are at high baseline risk for CLABSI (Category II).20

Systemic antibiotic prophylaxis. Routine systemic antibiotic prophylaxis during or after CVC insertion to reduce the risk of CLABSI is not recommended (Category IB).20 A recent Cochrane meta-analysis involving patients with cancer found no convincing evidence that prophylactic peptidoglycan administration prior to CVC insertion was associated with reduced CLABSI incidence.101 A recent study examining the effect of prophylactic cefazolin on CLABSI following port placement similarly found no benefit associated with antibiotic treatment.102

### Institutional Initiatives To Reduce CLABSI

Educational interventions. Educational programs that emphasize appropriate indications for CVC placement and programs that review proper procedures for catheter insertion and maintenance have both been shown to reduce the incidence of CLABSI in various settings.103-107 Although teaching CVC insertion using simulation techniques is a growing phenomenon, a recent systematic review found that this practice was associated with less frequent mechanical complications, but not CLABSI.108 Reporting and monitoring for infections through a structured infection control program is a critical component of CLABSI prevention. Consequently, education and training regarding how to implement and assess infection control measures and periodic reassessment of this knowledge has also been shown to reduce CLABSI.20,35,109 Despite these important studies, a recent survey found that knowledge regarding which practices are most associated with CLABSI prevention remains variable.110 Educational initiatives thus represent an important area of opportunity for institutions and health systems interested in controlling CLABSI (Category IA).20

Use of catheter checklists or “bundles.” A standardized approach to CVC placement that utilizes a set of evidence-based practices represents an important innovation in CLABSI prevention. In the Michigan Keystone ICU study, Pronovost and colleagues enrolled 103 ICUs in 67 hospitals to test whether an intervention consisting of five evidence-based practices implemented at the time of CVC insertion could reduce CLABSI. Notably, these five practices were selected because they each had strong evidence supporting their efficacy in CLABSI reduction and the lowest barriers to implementation. These five practices were hand hygiene prior to insertion; use of maximal sterile barrier precautions; chlorhexidine for skin antisepsis; avoidance of the femoral site of insertion; and prompt removal of catheters when no longer indicated. Following implementation of this intervention, the mean rate of CLABSI dropped from 7.7 per 1,000 catheter days at baseline to 1.4 per 1,000 catheter days at 16 months across participating sites.33 The use of these five interventions in unison has been called the “checklist” or “the bundle.” The use of the bundle and variations thereof has been associated with a sustained decrease in the incidence of CLABSI, not only within the U.S., but internationally as well.38,111-116 The bundle has also been found to be cost-effective both in the U. S. and abroad, leading to its widespread acceptance as a key strategy with which to reduce CLABSI.20,117 The HICPAC guidelines categorize the use of bundled interventions during CVC insertion as performance improvement initiatives and recommends this practice to reduce CLABSI (Category IB).20

Specialized CVC insertion teams. Data from several studies suggest that CVC placement by specialized teams dedicated to this role leads not only to greater placement skills and reduced insertion complications, but also to reduced rates of institutional CLABSI.25,33,38,111 The use of dedicated and trained staff ensures predictable adherence to evidence-based practices such as hand hygiene and maximal sterile barriers. The advent of nursing-led PICC teams represents an important transformation in the placement of CVCs in both critically ill and hospitalized patients. Preliminary studies suggest that these teams are associated with high rates of insertion success and low rates of mechanical complications in a variety of patient settings.118-120 However, no data comparing the risk of CLABSI in patients who undergo PICC placement by nursing PICC teams compared with other providers (such as hospitalists or radiologists) are currently available. The HICPAC guidelines recommend the use of trained personnel to insert CVCs (Category IA).20

## How Has CLABSI Prevention Been Implemented?

With the realization that CLABSI can be curtailed by the use of evidence-based practices, CLABSI prevention has increasingly become an attainable goal for hospitals, health care systems, and payors. The Michigan Keystone ICU study underscored how both technical (e.g., asepsis during insertion, standardized surveillance), and adaptive (e.g., buy-in from leadership, a culture of safety) components were needed to successfully implement a CLABSI prevention initiative.121 The identification of these two distinct, yet complementary, realms highlights how engagement and education of staff, consistent execution of the bundle, and rigorous evaluation of process—critical activities embodied within the CLABSI bundle—are fundamental components of CLABSI reduction.122 To ensure validity outside of Michigan, this model was replicated and tested in Rhode Island and in the Adventist multistate health care system, where declines in CLABSI at participating sites were also observed.122,123

Fueled by these successes, the U.S. Department of Health and Human Services prioritized CLABSI reduction by designating it as Tier I of a comprehensive national healthcare-associated infection prevention program. Ambitiously, the program aimed to reduce the incidence of CLABSI by 50 percent in ICUs and specific patient populations over a period of 5 years, primarily by encouraging the use of insertion bundles. A 2011 interim analysis found that providers are on track with meeting this target, although continued opportunities remain for patients in non-ICU settings and those receiving hemodialysis.124 In similar fashion, the Agency for Healthcare Research and Quality (AHRQ) funded and launched an implementation program called “On the CUSP: Stop BSI.” This national venture includes Federal agencies (e.g., CDC), State organizations, and various professional societies, and aims to reduce the mean CLABSI rate to less than 1 per 1,000 catheter days in each of the 50 United States.

## What Have We Learned About CLABSI Prevention?

A decade's worth of quality improvement, clinical research and policy change has led to greater understanding of a number of pivotal aspects of prevention and control of CLABSI. These important lessons and ongoing challenges are summarized below.

### Importance of Organizational Context

CLABSI reduction efforts using bundles have been successful at some sites, but not at others. This variable success has led to a renewed appreciation of organizational complexities (e.g., local culture, clinical care team engagement) that influence the implementation of evidence-based practices in health care settings. In a study that sought to answer why certain hospitals were more likely to succeed in CLABSI reduction efforts than others, Krein and colleagues found that themes involving structure and hierarchy within hospitals, politics and relationships between key stakeholders, a missing sense of mission and value, and lack of commitment and passion explained why some hospitals were not as successful at implementing CLABSI reduction practices as others. The authors suggest that the use of externally-facilitated initiatives (e.g., infection prevention measures, technology-based solutions or a quality collaborative), may provide the motivation, and sometimes resources, needed for implementation needed to implement CLABSI prevention measures and overcome these major obstacles.125 In another article studying the influence of context on outcomes, Dixon-Woods and colleagues examined the Michigan Keystone ICU-initiative to develop an ex-post theory of why this quality improvement program was so successful.126 These investigators posited that a number of components ensured the success of the program: (a) recruitment of a large number of ICUs that created pressure for others to join (e.g., isomorphic pressure), (b) the use of scheduled teleconferences and meetings that created a sense of a densely networked community, (c) reframing of CLABSI as a social problem (e.g., one that involved human action and behavior, not a technical fix), which convinced stakeholders that they should organize to solve this issue, (d) influencing hospital culture through checklists and integration of nursing and management, and (e), robust measurement of outcomes as a means to enforce practice.

Similar themes emerged from a multi-ICU study involving the Department of Veterans Affairs (VA) health care system, one of the largest integrated health care systems in the world. Render and colleagues studied the effects of a centralized inpatient evaluation center that supported not only bundle implementation, but also provided support by recruiting leadership, and providing feedback, learning tools, and mentoring at VA ICUs. Although the bundle was implemented in all ICUs, the investigators found marked declines in CLABSI specifically at sites where the additional support tools were well received. In contrast, sites that struggled with CLABSI reduction lacked a functional improvement team, forcing functions, or real-time feedback systems, underscoring the importance of these factors in CLABSI reduction.127

In a national study of 1,212 health care professionals from 33 different hospitals, Flanagan and colleagues conducted an open-ended survey and also found that poor adherence to guidelines, lack of culture change, no impetus to change, insufficient resources, and issues related to education were perceived barriers to achieving success in CLABSI improvement programs.128 In the context of the work by Krein, Dixon-Woods, and others, these findings highlight the importance of understanding, appreciating, and addressing contextual factors in the quest to control CLABSI throughout the world.

### Need for Accurate and Reliable Reporting

AHRQ has emphasized the reduction of CVC-associated BSI by designating it as Patient Safety Indicator (PSI)-7 on nationally reported scorecards. Although a technical brief outlining specifications of measurement for this PSI is publicly available,18 variations in measurement of this indicator have led to consternation in the literature. In a criterion validity study, Zrelak and colleagues conducted a retrospective cross-sectional study of 23 U.S. hospitals using trained abstractors and found that among 191 cases that met PSI-7 criteria, only 104 (positive predictive value [PPV] 54%; 95% CI, 40% to 69%) represented true CLABSI.129 In another study examining the validity of PSI-7, Cevasco and colleagues used similar methodology and found that only 42 of 112 reviewed cases represented true CLABSI events (PPV 38%; 95% CI, 29% to 47%).130 In both studies, coding-related issues and present-on-admission diagnoses explained a large fraction of incorrect reporting. Inaccurate measurement is further compounded by continued variation in public reporting of PSI-7. In a study of 14 states with mandatory CLABSI monitoring laws, Aswani and colleagues found numerous disparities in how participating sites selected the time span of their data collection, variably presented their infection rates, used inconsistent methods of risk adjustment, chose which locations and care settings to report, and demonstrated significant time lag to reporting.131 Using a standard definition of CLABSI to retrospectively study institutional variation in reporting bloodstream infections, Lin and colleagues found marked variability among 20 ICUs when comparing infection preventionists-reported CLABSI rates to those from a computer-generated algorithm.132 In a provocative study, Niedner and colleagues showed that more-aggressive surveillance using stricter definitions and written policies was associated with higher CLABSI reporting rates in 16 pediatric ICUs.133 This variability in reporting has profound implications in pay-for-performance and benchmarking applications that use this measure, as those most likely to accurately report CLABSI stand to be the most penalized. This dilemma underscores the need to standardize, audit, and constantly evaluate this system of quality measurement.

### Importance of Continued Performance Improvement Efforts

Despite major strides involving knowledge generation and dissemination over the past decade, important gaps remain in the practice of CLABSI prevention. In a cross-sectional survey of 1,000 randomly selected physician-members of the American College of Physicians-American Society of Internal Medicine, the reported use of maximal sterile barriers and chlorhexidine gluconate at the time of CVC insertion remained low among internists who identified themselves as having recently inserted a CVC.134 Similarly, around 15 percent of U.S. hospitals report routinely changing CVCs at predetermined time intervals despite abundant evidence that this practice should be discontinued.43,135 In an audit of staff practice and awareness of post-insertion catheter care, Shapey and colleagues found multiple breaches involving knowledge about dressing and catheter hub decontamination.136 Are these behaviors and practices remediable? In a 36-month followup study of the Keystone Project, zero incidents of CLABSI were found in participating sites, despite completion of the original study. The durability of this effect suggests that not only can behaviors be changed, but engagement, education, monitoring, and feedback can sustain these behaviors beyond the intervention stage.113 Ongoing performance measurement and process improvement must thus come to represent a fundamental facet of national and local efforts directed towards CLABSI prevention.

### Identification of New Challenges

Most BSIs related to CVCs occur not in those with long-term CVCs, but in patients with short-term CVCs.137 A major shift in the landscape of short-term CVCs, the remarkable growth of PICC use in hospitalized and critically ill patients, may therefore bring new challenges to CLABSI prevention.12,76,120 Despite the rapid growth in the use of PICCs, little is known about the indications, prevalence, and patterns of use of this device. Consequently, little is known regarding the adherence to or appropriateness of CLABSI prevention techniques when inserting and maintaining PICC lines. As PICCs are frequently placed in vulnerable populations such as children and those with cancer138 and are associated with important complications, further study of this technology and its association with CLABSI is needed.139,140 In addition, considerably less attention has been devoted to the study and testing of best practices in maintaining long-term CVCs, such as PICCs. As the risk of CLABSI is greatly influenced by the manner in which a CVC is handled and treated following insertion, this knowledge gap represents an important area for future study.

## Conclusions and Comment

The intervening decade between the original “Making Health Care Safer” report18,21,22 and this update has borne witness to a number of practices, approaches, and technologies that have controlled and eliminated CLABSI in specific settings. Despite this progress, a number of important policy, knowledge, and implementation gaps remain. While a CLABSI bundle that incorporates five practices that have reasonable evidence underlying their use appears to be successful in reducing CLABSI within ICUs, the extent to which this bundle is effective at preventing and reducing CLABSI outside of the ICU is unknown. As the majority of CVCs are now found in non-ICU settings, a research agenda that targets this population is necessary. Understanding how best to assess and address the complexities of culture and behavior are critical in this context, as these factors are likely to vary to a greater extent than ICU settings. A summary table is located in Table 2, Chapter 10.

Table 2, Chapter 10 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard is It?
Common/Moderate | Moderate-to-high | Low | Low-to-moderate | Moderate-to-difficult/Not difficult (implementation of a “bundle”)-to-moderate (understanding organization culture and context)

## References

1 United States Department of Health and Human Services. www.hhs.gov/ash/initiatives/hai/nationaltargets/index.html#table1]. 2011. February 7, 2012.
2 Klevens RM, Edwards JR, Richards CL Jr., et al. Estimating health care-associated infections and deaths in U.S. hospitals, 2002. Public Health Rep. Mar-Apr. 2007;122(2):160-6. [pmid: 17357358].
3 Horan TC, Andrus M, Dudeck MA. CDC/NHSN surveillance definition of health care-associated infection and criteria for specific types of infections in the acute care setting. Am J Infect Control. Jun. 2008;36(5):309-32. [pmid: 18538699].
4 CDC/NHSN Surveillance Definition of Healthcare-Associated Infection and Criteria for Specific Types of Infections in the Acute Care Setting. www.cdc.gov/nhsn/PDFs/pscManual/17pscNosInfDef_current.pdf. 2012. February 8, 2012.
5 Mermel LA, Allon M, Bouza E, et al. Clinical practice guidelines for the diagnosis and management of intravascular catheter-related infection: 2009 Update by the Infectious Diseases Society of America. Clin Infect Dis. Jul. 1. 2009;49(1):1-45. [pmid: 19489710].
6 Mermel LA. Prevention of central venous catheter-related infections: what works other than impregnated or coated catheters?. J Hosp Infect. Jun. Suppl 2. 2007;65:30-3. [pmid: 17540238].
7 Wenzel RP, Edmond MB. The impact of hospital-acquired bloodstream infections. Emerg Infect Dis. Mar-Apr. 2001;7(2):174-7. [pmid: 11294700].
8 Climo M, Diekema D, Warren DK, et al. Prevalence of the use of central venous access devices within and outside of the intensive care unit: results of a survey among hospitals in the prevention epicenter program of the Centers for Disease Control and Prevention. Infect Control Hosp Epidemiol. Dec. 2003;24(12):942-5. [pmid: 14700410].
9 Weber DJ, Sickbert-Bennett EE, Brown V, et al. Comparison of hospitalwide surveillance and targeted intensive care unit surveillance of healthcare-associated infections. Infect Control Hosp Epidemiol. Dec. 2007;28(12):1361-6. [pmid: 17994516].
10 Edwards JR, Peterson KD, Mu Y, et al. National Healthcare Safety Network (NHSN) report: data summary for 2006 through 2008, issued December 2009. Am J Infect Control. Dec. 2009;37(10):783-805. [pmid: 20004811].
11 Vital signs: central line-associated blood stream infections--United States, 2001, 2008, and 2009. MMWR Morb Mortal Wkly Rep. Mar. 4. 2011;60(8):243-8. [pmid: 21368740].
12 Ajenjo MC, Morley JC, Russo AJ, et al. Peripherally inserted central venous catheter-associated bloodstream infections in hospitalized adult patients. Infect Control Hosp Epidemiol. Feb. 2011;32(2):125-30. [pmid: 21460466].
13 Stone PW, Braccia D, Larson E. Systematic review of economic analyses of health care-associated infections. Am J Infect Control. Nov. 2005;33(9):501-9. [pmid: 16260325].
14 Scott R. The direct medical costs of healthcare-assicated infections in U.S. hospitals and the benefits of prevention. www.cdc.gov/HAI/pdfs/hai/Scott_CostPaper.pdf. January 30, 2012.
15 Roberts RR, Scott RD 2nd, Hota B, et al. Costs attributable to healthcare-acquired infection in hospitalized adults and a comparison of economic methods. Med Care. Nov. 2010;48(11):1026-35. [pmid: 20940650].
16 Tarricone R, Torbica A, Franzetti F, et al. Hospital costs of central line-associated bloodstream infections and cost-effectiveness of closed vs. open infusion containers. The case of Intensive Care Units in Italy. Cost Eff Resour Alloc. 2010;8:8. [pmid: 20459753].
17 Institute For Healthcare Improvement (IHI). Getting started kit: prevent central line infections how-to guide. www.ihi.org/IHI/Programs/Campaign/CentralLineInfection.htm. 2008. January 30, 2012.
18 Agency for Healthcare Quality and Research. PSI, Technical Specifications. www.qualityindicators.ahrq.gov/Downloads/Software/SAS/V43/TechnicalSpecifications/PSI%2007%20Central%20Venous%20Catheter-Related%20Blood%20Stream%20Infections.pdf. January 30, 2012.
19 Association for Professionals in Infection Control and Epidemiology. Targeting zero healthcare associated infections. www.apic.org/AM/CM/ContentDisplay.cfm?ContentFileID=11707. 2008. January 30, 2012.
20 O'Grady NP, Alexander M, Burns LA, et al. Guidelines for the prevention of intravascular catheter-related infections. Am J Infect Control. May. 2011;39(4 Suppl 1):S1-34. [pmid: 21511081].
21 Shojania KG, Duncan BW, McDonald KM, et al. Making health care safer: a critical analysis of patient safety practices. Evidence report/technology assessment (Summary). 2001;(43):i-x. 1. 668. [pmid: 11510252].
22 Saint S. Chapter 16. Prevention of Intravascular Catheter Associated Infections. Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report/Technology Assessment, No. 43. AHRQ Publication No. 01-E058. Agency for Healthcare Research and Quality. Rockville, MD. 2001:149-162. www.ahrq.gov/clinic/ptsafety/pdf/chap16.pdf.
23 Alonso-Echanove J, Edwards JR, Richards MJ, et al. Effect of nurse staffing and antimicrobial-impregnated central venous catheters on the risk for bloodstream infections in intensive care units. Infect Control Hosp Epidemiol. Dec. 2003;24(12):916-25. [pmid: 14700407].
24 Lorente L, Henry C, Martin MM, et al. Central venous catheter-related infection in a prospective and observational study of 2,595 catheters. Crit Care. 2005;9(6):R631-5. [pmid: 16280064].
25 Knoll BM, Wright D, Ellingson L, et al. Reduction of inappropriate urinary catheter use at a Veterans Affairs hospital through a multifaceted quality improvement project. Clin Infect Dis. Jun. 2011;52(11):1283-90. [pmid: 21596671].
26 Almuneef MA, Memish ZA, Balkhy HH, et al. Rate, risk factors and outcomes of catheter-related bloodstream infection in a paediatric intensive care unit in Saudi Arabia. J Hosp Infect. Feb. 2006;62(2):207-13. [pmid: 16307822].
27 Maki DG, Kluger DM, Crnich CJ. The risk of bloodstream infection in adults with different intravascular devices: a systematic review of 200 published prospective studies. Mayo Clin Proc. Sep. 2006;81(9):1159-71. [pmid: 16970212].
28 Yoshida J, Ishimaru T, Kikuchi T, et al. Association between risk of bloodstream infection and duration of use of totally implantable access ports and central lines: a 24-month study. Am J Infect Control. Sep. 2011;39(7):e39-43. [pmid: 21652113].
29 Bicudo D, Batista R, Furtado GH, et al. Risk factors for catheter-related bloodstream infection: a prospective multicenter study in Brazilian intensive care units. Braz J Infect Dis. Jul-Aug. 2011;15(4):328-31. [pmid: 21861002].
30 Safdar N, Kluger DM, Maki DG. A review of risk factors for catheter-related bloodstream infection caused by percutaneously inserted, noncuffed central venous catheters: implications for preventive strategies. Medicine (Baltimore). Nov. 2002;81(6):466-79. [pmid: 12441903].
31 Savolainen-Kopra C, Haapakoski J, Peltola PA, et al. Hand washing with soap and water together with behavioural recommendations prevents infections in common work environment: an open cluster-randomized trial. Trials. Jan. 16. 2012;13(1):10. [pmid: 22243622].
32 Bischoff WE, Reynolds TM, Sessler CN, et al. Handwashing compliance by health care workers: The impact of introducing an accessible, alcohol-based hand antiseptic. Arch Intern Med. Apr. 10. 2000;160(7):1017-21. [pmid: 10761968].
33 Pronovost P, Needham D, Berenholtz S, et al. An intervention to decrease catheter-related bloodstream infections in the ICU. N Engl J Med. Dec. 28. 2006;355(26):2725-32. [pmid: 17192537].
34 Barrera L, Zingg W, Mendez F, et al. Effectiveness of a hand hygiene promotion strategy using alcohol-based handrub in 6 intensive care units in Colombia. Am J Infect Control. Oct. 2011;39(8):633-9. [pmid: 21636170].
35 Zingg W, Imhof A, Maggiorini M, et al. Impact of a prevention strategy targeting hand hygiene and catheter care on the incidence of catheter-related bloodstream infections. Crit Care Med. Jul. 2009;37(7):2167-73. quiz 80. [pmid: 19487942].
36 Centers for Disease Control and Prevention. Guideline for Hand Hygiene in Health-Care Settings: Recommendations of the Healthcare Infection Control Practices Advisory Committee and the HICPAC/SHEA/APIC/IDSA Hand Hygiene Task Force. MMWR Morb Mortal Wkly Rep. 2002. 2002;51(No. RR- 16):1-32.
37 Young EM, Commiskey ML, Wilson SJ. Translating evidence into practice to prevent central venous catheter-associated bloodstream infections: a systems-based intervention. Am J Infect Control. Oct. 2006;34(8):503-6. [pmid: 17015155].
38 Berenholtz SM, Pronovost PJ, Lipsett PA, et al. Eliminating catheter-related bloodstream infections in the intensive care unit. Crit Care Med. Oct. 2004;32(10):2014-20. [pmid: 15483409].
39 Galpern D, Guerrero A, Tu A, et al. Effectiveness of a central line bundle campaign on line-associated infections in the intensive care unit. Surgery. Oct. 2008;144(4):492-5. discussion 5. [pmid: 18847630].
40 Raad II, Hohn DC, Gilbreath BJ, et al. Prevention of central venous catheter-related infections by using maximal sterile barrier precautions during insertion. Infect Control Hosp Epidemiol. Apr. 1994;15(4 Pt 1):231-8. [pmid: 8207189].
41 Hu KK, Veenstra DL, Lipsky BA, et al. Use of maximal sterile barriers during central venous catheter insertion: clinical and economic outcomes. Clin Infect Dis. Nov. 15. 2004;39(10):1441-5. [pmid: 15546079].
42 Rosenthal VD, Maki DG, Rodrigues C, et al. Impact of International Nosocomial Infection Control Consortium (INICC) strategy on central line-associated bloodstream infection rates in the intensive care units of 15 developing countries. Infect Control Hosp Epidemiol. Dec. 2010;31(12):1264-72. [pmid: 21029008].
43 Warren DK, Yokoe DS, Climo MW, et al. Preventing catheter-associated bloodstream infections: a survey of policies for insertion and care of central venous catheters from hospitals in the prevention epicenter program. Infect Control Hosp Epidemiol. Jan. 2006;27(1):8-13. [pmid: 16418980].
44 Krein SL, Kowalski CP, Hofer TP, et al. Preventing Hospital-Acquired Infections: A National Survey of Practices Reported by U.S. Hospitals in 2005 and 2009. J Gen Intern Med. 2011. Dec. 6. [pmid: 22143455].
45 Chaiyakunapruk N, Veenstra DL, Lipsky BA, et al. Chlorhexidine compared with povidone-iodine solution for vascular catheter-site care: a meta-analysis. Ann Intern Med. Jun. 4. 2002;136(11):792-801. [pmid: 12044127].
46 Chaiyakunapruk N, Veenstra DL, Lipsky BA, et al. Vascular catheter site care: the clinical and economic benefits of chlorhexidine gluconate compared with povidone iodine. Clin Infect Dis. Sep. 15. 2003;37(6):764-71. [pmid: 12955636].
47 Niel-Weise BS, Stijnen T, van den Broek PJ. Anti-infective-treated central venous catheters for total parenteral nutrition or chemotherapy: a systematic review. J Hosp Infect. Jun. 2008;69(2):114-23. [pmid: 18439717].
48 Niel-Weise BS, Stijnen T, van den Broek PJ. Anti-infective-treated central venous catheters: a systematic review of randomized controlled trials. Intensive Care Med. Dec. 2007;33(12):2058-68. [pmid: 17940746].
49 Casey AL, Mermel LA, Nightingale P, et al. Antimicrobial central venous catheters in adults: a systematic review and meta-analysis. Lancet Infect Dis. Dec. 2008;8(12):763-76. [pmid: 19022192].
50 Ramritu P, Halton K, Collignon P, et al. A systematic review comparing the relative effectiveness of antimicrobial-coated catheters in intensive care units. Am J Infect Control. Mar. 2008;36(2):104-17. [pmid: 18313512].
51 Hockenhull JC, Dwan KM, Smith GW, et al. The clinical effectiveness of central venous catheters treated with anti-infective agents in preventing catheter-related bloodstream infections: a systematic review. Crit Care Med. Feb. 2009;37(2):702-12. [pmid: 19114884].
52 Weber JM, Sheridan RL, Fagan S, et al. Incidence of Catheter-Associated Bloodstream Infection After Introduction of Minocycline and Rifampin Antimicrobial-Coated Catheters in a Pediatric Burn Population. J Burn Care Res. 2012. Jan. 2. [pmid: 22210071].
53 Rupp ME, Lisco SJ, Lipsett PA, et al. Effect of a second-generation venous catheter impregnated with chlorhexidine and silver sulfadiazine on central catheter-related infections: a randomized, controlled trial. Ann Intern Med. Oct. 18. 2005;143(8):570-80. [pmid: 16230723].
54 Cherry-Bukowiec JR, Denchev K, Dickinson S, et al. Prevention of catheter-related blood stream infection: back to basics?. Surg Infect (Larchmt). Feb. 2011;12(1):27-32. [pmid: 21171811].
55 Merrer J, De Jonghe B, Golliot F, et al. Complications of femoral and subclavian venous catheterization in critically ill patients: a randomized controlled trial. JAMA. Aug. 8. 2001;286(6):700-7. [pmid: 11495620].
56 van der Kooi TI, Wille JC, van Benthem BH. Catheter application, insertion vein and length of ICU stay prior to insertion affect the risk of catheter-related bloodstream infection. J Hosp Infect. 2012. Jan. 11. [pmid: 22243832].
57 Hamilton HC, Foxcroft DR. Central venous access sites for the prevention of venous thrombosis, stenosis and infection in patients requiring long-term intravenous therapy. Cochrane Database Syst Rev. 2007;(3):CD004084. [pmid: 17636746].
58 Goetz AM, Wagener MM, Miller JM, et al. Risk of infection due to central venous catheters: effect of site of placement and catheter type. Infect Control Hosp Epidemiol. Nov. 1998;19(11):842-5. [pmid: 9831940].
59 Lorente L, Jimenez A, Naranjo C, et al. Higher incidence of catheter-related bacteremia in jugular site with tracheostomy than in femoral site. Infect Control Hosp Epidemiol. Mar. 2010;31(3):311-3. [pmid: 20109074].
60 Casanegra AI, Brannan S, Dadu R, et al. Short-term femoral vein catheterization rarely causes thrombosis or bacteremia. J Hosp Med. Jan. 2011;6(1):33-6. [pmid: 20578050].
61 Reyes JA, Habash ML, Taylor RP. Femoral central venous catheters are not associated with higher rates of infection in the pediatric critical care population. Am J Infect Control. Feb. 2012;40(1):43-7. [pmid: 21704431].
62 Parienti JJ, Thirion M, Megarbane B, et al. Femoral vs jugular venous catheterization and risk of nosocomial events in adults requiring acute renal replacement therapy: a randomized controlled trial. JAMA. May. 28. 2008;299(20):2413-22. [pmid: 18505951].
63 Cookson ST, Ihrig M, O'Mara EM, et al. Increased bloodstream infection rates in surgical patients associated with variation from recommended use and care following implementation of a needleless device. Infect Control Hosp Epidemiol. Jan. 1998;19(1):23-7. [pmid: 9475345].
64 Rupp ME, Sholtz LA, Jourdan DR, et al. Outbreak of bloodstream infection temporally associated with the use of an intravascular needleless valve. Clin Infect Dis. Jun. 1. 2007;44(11):1408-14. [pmid: 17479934].
65 Maragakis LL, Bradley KL, Song X, et al. Increased catheter-related bloodstream infection rates after the introduction of a new mechanical valve intravenous access port. Infect Control Hosp Epidemiol. Jan. 2006;27(1):67-70. [pmid: 16418990].
66 Lockman JL, Heitmiller ES, Ascenzi JA, et al. Scrub the hub! Catheter needleless port decontamination. Anesthesiology. Apr. 2011;114(4):958. [pmid: 21270632].
67 Sannoh S, Clones B, Munoz J, et al. A multimodal approach to central venous catheter hub care can decrease catheter-related bloodstream infection. Am J Infect Control. Aug. 2010;38(6):424-9. [pmid: 20137829].
68 Soothill JS, Bravery K, Ho A, et al. A fall in bloodstream infections followed a change to 2% chlorhexidine in 70% isopropanol for catheter connection antisepsis: a pediatric single center before/after study on a hemopoietic stem cell transplant ward. Am J Infect Control. Oct. 2009;37(8):626-30. [pmid: 19616869].
69 Simmons S, Bryson C, Porter S. “Scrub the hub”: cleaning duration and reduction in bacterial load on central venous catheters. Crit Care Nurs Q. Jan-Mar. 2011;34(1):31-5. [pmid: 21160298].
70 Maki DG. In vitro studies of a novel antimicrobial luer-activated needleless connector for prevention of catheter-related bloodstream infection. Clin Infect Dis. Jun. 15. 2010;50(12):1580-7. [pmid: 20455695].
71 Menyhay SZ, Maki DG. Disinfection of needleless catheter connectors and access ports with alcohol may not prevent microbial entry: the promise of a novel antiseptic-barrier cap. Infect Control Hosp Epidemiol. Jan. 2006;27(1):23-7. [pmid: 16418982].
72 Menyhay SZ, Maki DG. Preventing central venous catheter-associated bloodstream infections: development of an antiseptic barrier cap for needleless connectors. Am J Infect Control. Dec. 2008;36(10):S174 e1-5. [pmid: 19084153].
73 Buchman AL, Spapperi J, Leopold P. A new central venous catheter cap: decreased microbial growth and risk for catheter-related bloodstream infection. J Vasc Access. Jan-Mar. 2009;10(1):11-21. [pmid: 19340794].
74 Oto J, Imanaka H, Konno M, et al. A prospective clinical trial on prevention of catheter contamination using the hub protection cap for needleless injection device. Am J Infect Control. May. 2011;39(4):309-13. [pmid: 20965611].
75 Lederle FA, Parenti CM, Berskow LC, et al. The idle intravenous catheter. Ann Intern Med. May. 1. 1992;116(9):737-8. [pmid: 1558345].
76 Tejedor SC, Tong D, Stein J, et al. Temporary central venous catheter utilization patterns in a large tertiary care center: tracking the “idle central venous catheter”. Infect Control Hosp Epidemiol. Jan. 2012;33(1):50-7. [pmid: 22173522].
77 Zingg W, Sandoz L, Inan C, et al. Hospital-wide survey of the use of central venous catheters. J Hosp Infect. Apr. 2011;77(4):304-8. [pmid: 21288595].
78 Bleasdale SC, Trick WE, Gonzalez IM, et al. Effectiveness of chlorhexidine bathing to reduce catheter-associated bloodstream infections in medical intensive care unit patients. Arch Intern Med. Oct. 22. 2007;167(19):2073-9. [pmid: 17954801].
79 Dixon JM, Carver RL. Daily chlorohexidine gluconate bathing with impregnated cloths results in statistically significant reduction in central line-associated bloodstream infections. Am J Infect Control. Dec. 2010;38(10):817-21. [pmid: 21093698].
80 Munoz-Price LS, Hota B, Stemer A, et al. Prevention of bloodstream infections by use of daily chlorhexidine baths for patients at a long-term acute care hospital. Infect Control Hosp Epidemiol. Nov. 2009;30(11):1031-5. [pmid: 19751155].
81 Popovich KJ, Hota B, Hayes R, et al. Daily skin cleansing with chlorhexidine did not reduce the rate of central-line associated bloodstream infection in a surgical intensive care unit. Intensive Care Med. May. 2010;36(5):854-8. [pmid: 20213074].
82 O'Horo JC, Silva GL, Munoz-Price LS, et al. The Efficacy of Daily Bathing with Chlorhexidine for Reducing Healthcare-Associated Bloodstream Infections: A Meta-analysis. Infect Control Hosp Epidemiol. Mar. 2012;33(3):257-67. [pmid: 22314063].
83 Hoffmann KK, Weber DJ, Samsa GP, et al. Transparent polyurethane film as an intravenous catheter dressing. A meta-analysis of the infection risks. JAMA. Apr. 15. 1992;267(15):2072-6. [pmid: 1532429].
84 Gillies D, O'Riordan E, Carr D, et al. Central venous catheter dressings: a systematic review. J Adv Nurs. Dec. 2003;44(6):623-32. [pmid: 14651685].
85 Timsit JF, Schwebel C, Bouadma L, et al. Chlorhexidine-impregnated sponges and less frequent dressing changes for prevention of catheter-related infections in critically ill adults: a randomized controlled trial. JAMA. Mar. 25. 2009;301(12):1231-41. [pmid: 19318651].
86 Schwebel C, Lucet JC, Vesin A, et al. Economic evaluation of chlorhexidine-impregnated sponges for preventing catheter-related infections in critically ill adults in the Dressing Study*. Crit Care Med. Jan. 2012;40(1):11-7. [pmid: 21926570].
87 Ye X, Rupnow M, Bastide P, et al. Economic impact of use of chlorhexidine-impregnated sponge dressing for prevention of central line-associated infections in the United States. Am J Infect Control. Oct. 2011;39(8):647-54. [pmid: 21641681].
88 Battistella M, Bhola C, Lok CE. Long-term follow-up of the Hemodialysis Infection Prevention with Polysporin Ointment (HIPPO) Study: a quality improvement report. Am J Kidney Dis. Mar. 2011;57(3):432-41. [pmid: 21216512].
89 Lok CE, Mokrzycki MH. Prevention and management of catheter-related infection in hemodialysis patients. Kidney Int. Mar. 2011;79(6):587-98. [pmid: 21178979].
90 Camins BC, Richmond AM, Dyer KL, et al. A crossover intervention trial evaluating the efficacy of a chlorhexidine-impregnated sponge in reducing catheter-related bloodstream infections among patients undergoing hemodialysis. Infect Control Hosp Epidemiol. Nov. 2010;31(11):1118-23. [pmid: 20879855].
91 Zakrzewska-Bode A, Muytjens HL, Liem KD, et al. Mupirocin resistance in coagulase-negative staphylococci, after topical prophylaxis for the reduction of colonization of central venous catheters. J Hosp Infect. Nov. 1995;31(3):189-93. [pmid: 8586787].
92 Flowers RH 3rd, Schwenzer KJ, Kopel RF, et al. Efficacy of an attachable subcutaneous cuff for the prevention of intravascular catheter-related infection. A randomized, controlled trial. JAMA. Feb. 10. 1989;261(6):878-83. [pmid: 2492354].
93 Safdar N, Maki DG. Use of vancomycin-containing lock or flush solutions for prevention of bloodstream infection associated with central venous access devices: a meta-analysis of prospective, randomized trials. Clin Infect Dis. Aug. 15. 2006;43(4):474-84. [pmid: 16838237].
94 O'Horo JC, Silva GL, Safdar N. Anti-infective locks for treatment of central line-associated bloodstream infection: a systematic review and meta-analysis. Am J Nephrol. 2011;34(5):415-22. [pmid: 21934302].
95 Campos RP, do Nascimento MM, Chula DC, et al. Minocycline-EDTA lock solution prevents catheter-related bacteremia in hemodialysis. J Am Soc Nephrol. Oct. 2011;22(10):1939-45. [pmid: 21852579].
96 Toure A, Lauverjat M, Peraldi C, et al. Taurolidine lock solution in the secondary prevention of central venous catheter-associated bloodstream infection in home parenteral nutrition patients. Clin Nutr. 2012. Jan. 27. [pmid: 22285029].
97 Moran J, Sun S, Khababa I, et al. A randomized trial comparing gentamicin/citrate and heparin locks for central venous catheters in maintenance hemodialysis patients. Am J Kidney Dis. Jan. 2012;59(1):102-7. [pmid: 22088576].
98 Mortazavi M, Alsaeidi S, Sobhani R, et al. Successful prevention of tunneled, central catheter infection by antibiotic lock therapy using cefotaxime. J Res Med Sci. Mar. 2011;16(3):303-9. [pmid: 22091249].
99 John BK, Khan MA, Speerhas R, et al. Ethanol Lock Therapy in Reducing Catheter-Related Bloodstream Infections in Adult Home Parenteral Nutrition Patients: Results of a Retrospective Study. JPEN J Parenter Enteral Nutr. 2011. Dec. 28. [pmid: 22205580].
100 Wales PW, Kosar C, Carricato M, et al. Ethanol lock therapy to reduce the incidence of catheter-related bloodstream infections in home parenteral nutrition patients with intestinal failure: preliminary experience. J Pediatr Surg. May. 2011;46(5):951-6. [pmid: 21616259].
101 van de Wetering MD, van Woensel JB. Prophylactic antibiotics for preventing early central venous catheter Gram positive infections in oncology patients. Cochrane Database Syst Rev. 2007;(1):CD003295. [pmid: 17253487].
102 Karanlik H, Kurul S, Saip P, et al. The role of antibiotic prophylaxis in totally implantable venous access device placement: results of a single-center prospective randomized trial. American journal of surgery. Jul. 2011;202(1):10-5. [pmid: 21601826].
103 Neumayer LA. Improving outcomes: the importance of data monitoring and ongoing educational interventions. Arch Surg. Mar. 2011;146(3):307. [pmid: 21542189].
104 Ong A, Dysert K, Herbert C, et al. Trends in central line-associated bloodstream infections in a trauma-surgical intensive care unit. Arch Surg. Mar. 2011;146(3):302-7. [pmid: 21422361].
105 Khouli H, Jahnes K, Shapiro J, et al. Performance of medical residents in sterile techniques during central vein catheterization: randomized trial of efficacy of simulation-based training. Chest. Jan. 2011;139(1):80-7. [pmid: 20705795].
106 Leung TK, Lee CM, Tai CJ, et al. A retrospective study on the long-term placement of peripherally inserted central catheters and the importance of nursing care and education. Cancer Nurs. Jan-Feb. 2011;34(1):E25-30. [pmid: 20885304].
107 Cohen ER, Feinglass J, Barsuk JH, et al. Cost savings from reduced catheter-related bloodstream infection after simulation-based education for residents in a medical intensive care unit. Simul Healthc. Apr. 2010;5(2):98-102. [pmid: 20389233].
108 Ma IW, Brindle ME, Ronksley PE, et al. Use of simulation-based education to improve outcomes of central venous catheterization: a systematic review and meta-analysis. Acad Med. Sep. 2011;86(9):1137-47. [pmid: 21785310].
109 Perez Parra A, Cruz Menarguez M, Perez Granda MJ, et al. A simple educational intervention to decrease incidence of central line-associated bloodstream infection (CLABSI) in intensive care units with low baseline incidence of CLABSI. Infect Control Hosp Epidemiol. Sep. 2010;31(9):964-7. [pmid: 20658936].
110 Koutzavekiaris I, Vouloumanou EK, Gourni M, et al. Knowledge and practices regarding prevention of infections associated with central venous catheters: a survey of intensive care unit medical and nursing staff. Am J Infect Control. Sep. 2011;39(7):542-7. [pmid: 21496955].
111 Wheeler DS, Giaccone MJ, Hutchinson N, et al. A hospital-wide quality-improvement collaborative to reduce catheter-associated bloodstream infections. Pediatrics. Oct. 2011;128(4):e995-e1004. quiz e-7. [pmid: 21930547].
112 Kim JS, Holtom P, Vigen C. Reduction of catheter-related bloodstream infections through the use of a central venous line bundle: epidemiologic and economic consequences. Am J Infect Control. Oct. 2011;39(8):640-6. [pmid: 21641088].
113 Pronovost PJ, Goeschel CA, Colantuoni E, et al. Sustaining reductions in catheter related bloodstream infections in Michigan intensive care units: observational study. BMJ. 2010;340:c309. [pmid: 20133365].
114 Longmate AG, Ellis KS, Boyle L, et al. Elimination of central-venous-catheter-related bloodstream infections from the intensive care unit. BMJ Qual Saf. Feb. 2011;20(2):174-80. [pmid: 21303772].
115 Chuengchitraks S, Sirithangkul S, Staworn D, et al. Impact of new practice guideline to prevent catheter-related blood stream infection (CRBSI): experience at the Pediatric Intensive Care Unit of Phramongkutklao Hospital. J Med Assoc Thai. Nov. Suppl 6. 2010;93:S79-83. [pmid: 21284138].
116 Palomar Martinez M, Alvarez Lerma F, Riera Badia MA, et al. Prevention of bacteriema related with ICU catheters by multifactorial intervention: a report of the pilot study. Med Intensiva. Dec. 2010;34(9):581-9. [pmid: 21041004].
117 Halton KA, Cook D, Paterson DL, et al. Cost-effectiveness of a central venous catheter care bundle. PLoS One. 2010;5(9). [pmid: 20862246].
118 Gamulka B, Mendoza C, Connolly B. Evaluation of a unique, nurse-inserted, peripherally inserted central catheter program. Pediatrics. Jun. 2005;115(6):1602-6. [pmid: 15930222].
119 Wang D, Amesur N, Shukla G, et al. Peripherally inserted central catheter placement with the sonic flashlight: initial clinical trial by nurses. J Ultrasound Med. May. 2009;28(5):651-6. [pmid: 19389904].
120 DeLemos C, Abi-Nader J, Akins PT. Use of peripherally inserted central catheters as an alternative to central catheters in neurocritical care units. Crit Care Nurse. Apr. 2011;31(2):70-5. [pmid: 21459866].
121 Pronovost PJ, Berenholtz SM, Needham DM. Translating evidence into practice: a model for large scale knowledge translation. BMJ. 2008;337:a1714. [pmid: 18838424].
122 Pronovost P. Interventions to decrease catheter-related bloodstream infections in the ICU: the Keystone Intensive Care Unit Project. Am J Infect Control. Dec. 2008;36(10):S171 e1-5. [pmid: 19084146].
123 DePalo VA, McNicoll L, Cornell M, et al. The Rhode Island ICU collaborative: a model for reducing central line-associated bloodstream infection and ventilator-associated pneumonia statewide. Qual Saf Health Care. Dec. 2010;19(6):555-61. [pmid: 21127114].
124 United States Department of Health and Human Services: Healthcare Associated Infection Prevention Plan. www.hhs.gov/ash/initiatives/hai/nationaltargets/index.html#table1. 2011. February 7, 2012.
125 Krein SL, Damschroder LJ, Kowalski CP, et al. The influence of organizational context on quality improvement and patient safety efforts in infection prevention: a multi-center qualitative study. Soc Sci Med. Nov. 2010;71(9):1692-701. [pmid: 20850918].
126 Dixon-Woods M, Bosk CL, Aveling EL, et al. Explaining Michigan: developing an ex post theory of a quality improvement program. Milbank Q. Jun. 2011;89(2):167-205. [pmid: 21676020].
127 Render ML, Hasselbeck R, Freyberg RW, et al. Reduction of central line infections in Veterans Administration intensive care units: an observational cohort using a central infrastructure to support learning and improvement. BMJ Qual Saf. Aug. 2011;20(8):725-32. [pmid: 21460392].
128 Flanagan ME, Welsh CA, Kiess C, et al. A national collaborative for reducing health care–associated infections: current initiatives, challenges, and opportunities. American Journal of Infection Control. 2011;39(8):685-9. [pmid: 21665329].
129 Zrelak PA, Sadeghi B, Utter GH, et al. Positive predictive value of the Agency for Healthcare Research and Quality Patient Safety Indicator for central line-related bloodstream infection (“selected infections due to medical care”). J Healthc Qual. Mar-Apr. 2011;33(2):29-36. [pmid: 21385278].
130 Cevasco M, Borzecki AM, O'Brien WJ, et al. Validity of the AHRQ Patient Safety Indicator “central venous catheter-related bloodstream infections”. J Am Coll Surg. Jun. 2011;212(6):984-90. [pmid: 21489833].
131 Aswani MS, Reagan J, Jin L, et al. Variation in public reporting of central line-associated bloodstream infections by state. Am J Med Qual. Sep-Oct. 2011;26(5):387-95. [pmid: 21825038].
132 Lin MY, Hota B, Khan YM, et al. Quality of traditional surveillance for public reporting of nosocomial bloodstream infection rates. JAMA. Nov. 10. 2010;304(18):2035-41. [pmid: 21063013].
133 Niedner MF. The harder you look, the more you find: Catheter-associated bloodstream infection surveillance variability. Am J Infect Control. Oct. 2010;38(8):585-95. [pmid: 20868929].
134 Rubinson L, Wu AW, Haponik EE, et al. Why is it that internists do not follow guidelines for preventing intravascular catheter infections?. Infect Control Hosp Epidemiol. Jun. 2005;26(6):525-33. [pmid: 16018427].
135 Krein SL, Hofer TP, Kowalski CP, et al. Use of central venous catheter-related bloodstream infection prevention practices by US hospitals. Mayo Clin Proc. Jun. 2007;82(6):672-8. [pmid: 17550746].
136 Shapey IM, Foster MA, Whitehouse T, et al. Central venous catheter-related bloodstream infections: improving post-insertion catheter care. J Hosp Infect. Feb. 2009;71(2):117-22. [pmid: 19013680].
137 O'Grady NP, Chertow DS. Managing bloodstream infections in patients who have short-term central venous catheters. Cleve Clin J Med. Jan. 2011;78(1):10-7. [pmid: 21199902].
138 Barrier A, Williams DJ, Connelly M, et al. Frequency of peripherally inserted central catheter complications in children. Pediatr Infect Dis J. 2011. Dec. 23. [pmid: 22189533].
139 Pikwer A, Akeson J, Lindgren S. Complications associated with peripheral or central routes for central venous cannulation. Anaesthesia. Jan. 2012;67(1):65-71. [pmid: 21972789].
140 Marnejon T, Angelo D, Abu Abdou A, et al. Risk factors for upper extremity venous thrombosis associated with peripherally inserted central venous catheters. J Vasc Access. 2012. Jan. 9. 0. [pmid: 22266584].