# Introduction

The modern patient safety movement is believed by many to trace its origins to the 1999 publication of the groundbreaking report, “To Err is Human” by the Institute of Medicine.1 This report, which highlighted the 44,000 to 98,000 deaths per year from medical errors in the United States (U.S.) (the equivalent of the fatalities that would result from the crash of a “jumbo jet a day”), galvanized the public and resulted in the focus, of widespread media and legislative attention, for the first time, on the issue of patient safety. Parallel reports from other countries were similarly influential.2

As part of its initial portfolio of patient safety activities, the Agency for Healthcare Research and Quality (AHRQ) commissioned a team from the University of California, San Francisco (UCSF)-Stanford University Evidence-Based Practice Center to analyze the evidence behind a diverse group of patient safety practices (PSPs) in use—or conceptualized—at that time. The report—”Making Health Care Safer: A Critical Analysis of Patient Safety Practices”2 (MHCS)—was published in 2001.^3^ The report analyzed nearly 80 different safety practices on several dimensions, including potential impact, supporting evidence, and costs and complexity of implementation. Based on these evidence reviews, practices were ultimately rated on both impact and evidence, as well as prioritization for future research.

MHCS was immediately both influential and controversial. Several hundred thousand copies of the report were distributed by AHRQ, and it became a lynchpin for other efforts (such as the National Quality Forum's Safe Practices list) to describe PSPs through the lens of evidence-based medicine. The controversy was generated by the report's rankings of PSPs—in particular, the relatively low rankings for certain popular practices such as computerized order entry—which raised fundamental questions about the role of evidence in assessing the value of quality and safety practices, questions that continue to be debated to this day.4-7

In 2001, hospitals and health care organizations were under relatively little pressure to implement safety practices. A decade later, the stakes have grown far higher.8 Regulators and accreditors are pushing health care organizations to adopt various “safe practices” or to avoid particular adverse events that are considered wholly or largely preventable. Many payers, including the Centers for Medicare & Medicaid Services, have embedded patient safety into pay-for-performance and “no pay for errors” initiatives. Billions of dollars and millions of person-hours have been invested in a variety of efforts to improve safety, and virtually every health care delivery organization now identifies patient safety as one of its top strategic priorities.

Yet the evidence indicates that our progress in eradicating medical errors has not matched the efforts and financial resources invested in implementing PSPs. Studies of some practices that have tremendous intuitive appeal, such as reducing resident duty hours and implementing rapid response teams, have yielded conflicting results.9,10 Many examples of unintended consequences of safety practices have emerged,11 and the successful implementation of safety practices has been shown to be highly context dependent,12 often working effectively in some hospitals but not others. Although a national initiative to improve safety in the United Kingdom found some evidence of improvement, control hospitals improved as much as those that participated in a vigorous intervention.13 Three recent U.S. studies have demonstrated continuing high rates of preventable harm in hospitals;14-16 one of these studies showed evidence of no improvement in adverse event rates from 2003 to 2008.^14^

Against this backdrop, AHRQ, believing that the time has come to re-examine the state of the evidence supporting a wide variety of PSPs, commissioned a team led by investigators at RAND Health, UCSF, and Johns Hopkins to reexamine the evidence behind key PSPs. Many of the individuals engaged in this task participated in producing the original MHCS report, the MCHS methodology formed the cornerstone of the present effort, and many of the practices examined for this report were those previously reviewed in 2001. Thus, we see the present report as a natural sequel to MHCS.

Because of the burgeoning literature relevant to patient safety and the limits of budget and time, we selected a subset of PSPs to examine for this present report (chosen through methods described in Chapter 2) rather than attempt, as we did in 2001, to review all PSPs. Moreover, the maturation of the safety field has led to a deeper appreciation of the importance of context in PSPs, a topic examined by our research team in our 2010 report, “Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices: Developing Criteria.”17 Accordingly, this report emphasizes matters of context and generalizability, as well as unintended consequences, to a greater degree than did MHCS.

## Who Will Use This Report, and for What Purpose?

We envision that this report will be useful to a wide audience.

Policymakers may use its contents and recommendations to promote or fund the implementation of particular practices. Similarly, leaders of local health care organization (including hospitals, medical groups, or integrated delivery systems) may use the data and analyses to choose which practices to consider implementing or further promote at their institutions. Because of consumers' keen interest in patient safety, the connection between the emergence of an evidence-based practice and the enactment of an associated accreditation standard, regulation, public reporting requirement, or payment-based initiative is much tighter for PSPs than it is for clinical practices. This makes it particularly crucial that policymakers have good data on which to base their decisions.

Clinicians are increasingly being asked to participate in patient safety activities and want to know the evidence supporting PSPs that they are being asked to help implement. For trainees and teachers, patient safety is now seen as foundational to the education of doctors, nurses, pharmacists, health care administrators, and other ancillary health care personnel. We hope that trainees and practicing clinicians alike will find the material both interesting and relevant to their day-to-day practices.

Researchers will find a wealth of potential research opportunities. Those who fund research, including (but not limited to) AHRQ, will find that we explicitly identified future research needs. As our understanding of the patient safety field has matured, researchers have become increasingly aware of the complexity of PSPs. For example, the widespread enthusiasm for the use of checklists18 (which was largely absent in 2001) has led to cautionary notes from several patient safety leaders regarding the degree to which even seemingly simple PSPs are dependent on culture change and local context.19,20

Patient safety professionals, meaning people directly involved in improving patient safety and those working in organizations focused on quality and patient safety, overlap with each of the three groups above, but deserve their own designation here, as they may be the most frequent and intense users of this report as they seek to improve patient safety at their own institutions.

Finally, while this volume is not primarily written for patients and their families, both groups have become increasingly involved in patient safety efforts in a variety of ways. We welcome such engagement and believe that patients, families, and their advocates can help advance efforts to prevent harm.

A decade ago, our early enthusiasm for patient safety was accompanied by a hope—and some magical thinking—that finding solutions to medical errors would be relatively straightforward. Simply adopt some techniques drawn from aviation and other “safe industries,” build strong information technology systems, and improve culture, and, the hope went, patients would immediately become safer in hospitals and clinics everywhere.

We now appreciate the naivety of this point of view. Making patients safe will require ongoing efforts to improve practices, training, information technology, and culture. It will need top-down resources and leadership, accompanied by bottom-up wisdom and innovation. It will depend on a strong policy environment that creates appropriate incentives, while avoiding an environment in which providers' enthusiasm and creativity are sapped by an overly rigid, prescriptive bureaucracy and set of rules.

While we have become more sophisticated about the challenges of keeping patients safe over the past decade, the fundamentals have not changed: we need good and well-trained people, armed with good data, operating under good policies, working under good leaders to do the right things for patients. We hope this report contributes to these efforts by helping to identify those right things.

## References

1 Kohn L, Corrigan J, Donaldson M, editors. To Err is Human: Building a Safer Health System. Washington, DC. Committee on Quality of Health Care in America, Institute of Medicine: National Academy Press. 2000.
2 Donaldson L. An Organisation with a Memory: Report of an Expert Group on Learning from Adverse Events in the NHS Chaired by the Chief Medical Officer. London. The Stationery Office. 2000.
3 Shojania KG, Duncan BW, McDonald KM, editors. Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report/Technology Assessment No. 43. AHRQ Publication No. 01-E058. Rockville, MD. Agency for Healthcare Research and Quality. 2001.
4 Shojania KG, Duncan BW, McDonald KM, et al. Safe but sound: patient safety meets evidence-based medicine. JAMA. 2002;288:508-513. [pmid: 12132985].
5 Leape LL, Berwick DM, Bates DW. What practices will most improve safety? Evidence-based medicine meets patient safety. JAMA. 2002;288:501-507. [pmid: 12132984].
6 Auerbach AD, Landefeld CS, Shojania KG. The tension between needing to improve care and knowing how to do it. N Engl J Med. 2007;357:608-613. [pmid: 17687138].
7 Berwick DM. The science of improvement. JAMA. 2008;299:1182-1184. [pmid: 18334694].
8 Wachter RM. Patient safety at ten: unmistakable progress, troubling gaps. Health Aff (Millwood). 2010;29:165-173. [pmid: 19952010].
9 Shetty KD, Bhattacharya J. Changes in hospital mortality associated with residency work-hour regulations. Ann Intern Med. 2007;147:73-80. [pmid: 17548403].
10 Chan PS, Jain R, Nallmothu BK, et al. Rapid response teams: a systematic review and meta-analysis. Arch Intern Med. 2010;170:18-26. [pmid: 20065195].
11 Sittig DF, Singh H. Defining health information technology–related errors: new developments since ‘to err is human’. Arch Intern Med. 2011;171:1281-1284. [pmid: 21788544].
12 Shekelle PG, Pronovost PJ, Wachter RM, et al. Advancing the science of patient safety. Ann Intern Med. 2011;154:693-696. [pmid: 21576538].
13 Benning A, Dixon-Woods M, Nwulu U, et al. Multiple component patient safety intervention in English hospitals: controlled evaluation of second phase. BMJ. 2011;342:d199. [pmid: 21292720].
14 Landrigan CP, Parry GJ, Bones CB, et al. Temporal trends in rates of patient harm resulting from medical care. N Engl J Med. 2010;363:2124-2134. [pmid: 21105794].
15 Classen DC, Resar R, Griffi n F, et al. ‘Global Trigger Tool’ shows that adverse events in hospitals may be ten times greater than previously measured. Health Aff (Millwood). 2011;30:581-589. [pmid: 21471476].
16 Levinson DR. Adverse Events in Hospitals: National Incidence Among Medicare Beneficiaries. Washington, DC. U.S. Department of Health and Human Services, Office of the Inspector General. November. 2010. Report No. OEI-06-09-00090.
17 Shekelle PG, Pronovost PJ, Wachter RM, et al. Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices: Developing Criteria. Contract Final Report. AHRQ Publication No. 11-0006-EF. December. 2010. Prepared under Contract No. HHSA-290-2009-10001C. Agency for Healthcare Research and Quality. Rockville, MD. www.ahrq.gov/qual/contextsensitive/.
18 Pronovost P, Needham D, Berenholtz S, et al. An intervention to decrease catheter related bloodstream infections in the ICU. N Engl J Med. 2006;355:2725-2732. [pmid: 17192537].
19 Bosk CL, Dixon-Woods M, Goeschel CA, et al. Reality check for checklists. Lancet. 2009;374:444-445. [pmid: 19681190].
20 Dixon-Woods M, Bosk CL, Aveling EL, et al. Explaining Michigan: developing an ex post theory of a quality improvement program. Milbank Q. 2011;89:167-205. [pmid: 21676020].