# Supplementary Evidence Tables

## Evidence Tables for Chapter 3 High-Alert Drugs: Patient Safety Practices for Intravenous Anticoagulants

Table 1, Chapter 3 Evidence table

## Evidence Tables for Chapter 4 The Clinical Pharmacist's Role in Preventing Adverse Drug Events: Brief Update Review

This brief review had no additional evidence tables. There is one table in the text.

## Evidence Tables for Chapter 5 The Joint Commission's “Do Not Use” List: Brief Review (NEW)

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 6 Smart Pumps and Other Protocols for Infusion Pumps: Brief Review (NEW)

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 7 Barrier Precautions, Patient Isolation, and Routine Surveillance for the Prevention of Healthcare-Associated Infections: Brief Update Review

Table 1, Chapter 7 Evidence table

## Evidence Tables for Chapter 8 Interventions To Improve Hand Hygiene Compliance: Brief Update Review

This brief review had no additional evidence tables

## Evidence Tables for Chapter 9 Reducing Unnecessary Urinary Catheter Use and Other Strategies To Prevent Catheter-Associated Urinary Tract Infection: Brief Update Review

Table 1, Chapter 9 Characteristics of studies with interventions to avoid unnecessary urinary catheter use

## Evidence Tables for Chapter 10 Prevention of Central Line-Associated Bloodstream Infections: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 11 Ventilator-Associated Pneumonia: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 12 Interventions to Allow the Reuse of Single-Use Devices: Brief Review (NEW)

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 13 Preoperative Checklists and Anesthesia Checklists

Table 1, Chapter 13 Studies of the World Health Organization surgical safety checklist at other locations

Table 2, Chapter 13 Implementation findings in studies of the World Health Organization surgical safety checklist at other locations

Table 3, Chapter 13 Studies of wrong-site-surgery checklists implementing the universal protocol

Table 4, Chapter 13 Studies of anesthesia equipment checklist implementation

## Evidence Tables for Chapter 14 Use of Report Cards and Outcome Measurements To Improve the Safety of Surgical Care: American College of Surgeons National Quality Improvement Program (NEW)

This review had no additional evidence tables. There is one evidence table in the text.

## Evidence Tables for Chapter 15 Prevention of Surgical Items Being Left Inside A Patient: Brief Update Review

This review had no additional evidence tables.

## Evidence Tables for Chapter 16 Operating Room Integration and Display Systems: Brief Review (NEW)

This review had no additional evidence tables.

## Evidence Tables for Chapter 17 Use of Beta Blockers To Prevent Perioperative Cardiac Events: Brief Update Review

This review had no additional evidence tables.

## Evidence Tables for Chapter 18 Use of Real-Time Ultrasound Guidance During Central Line Insertion: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 19 Preventing In-Facility Falls

This topic modifies an evidence table from an existing systematic review, and therefore some of the columns and entries are different than our normal format.

Table 1, Chapter 19 Evidence table adapted from Oliver and colleagues

Table 2, Chapter 19 Stenvall et al. 2007, Main content of the postoperative program and differences between the two groups: teamwork

Table 3, Chapter 19 Implementation studies evidence table

## Evidence Tables for Chapter 20 Preventing In-Facility Delirium

Table 1, Chapter 20 Risk factors for delirium

Table 2, Chapter 20 Delirium prevention—multi-component interventions

Table 3, Chapter 20 Delirium prevention—single interventions

## Evidence Tables for Chapter 21 Preventing In-Facility Pressure Ulcers

Table 1, Chapter 21 Multi-component pressure ulcer prevention initiatives conducted in acute care settings in the United States

Table 2, Chapter 21 Multi-component pressure ulcer prevention initiatives conducted in long-term care settings in the United States

## Evidence Tables for Chapter 22 Inpatient Intensive Glucose Control Strategies To Reduce Death and Infection (NEW)

Table 1, Chapter 22 Large trials (n > 500) evaluating the health outcome effects of IIT

## Evidence Tables for Chapter 23 Interventions To Prevent Contrast-Induced Acute Kidney Injury

Table 1, Chapter 23 Included studies

## Evidence Tables for Chapter 24 Rapid Response Systems (NEW)

Table 1, Chapter 24 RRS evidence table: effectiveness

Table 2, Chapter 24 Implementation table—RRS

Table 3, Chapter 24 Patient safety-RRT: risk of bias

## Evidence Tables for Chapter 25 Medication Reconciliation Supported by Clinical Pharmacists (NEW)

This review had no additional evidence tables.

## Evidence Tables for Chapter 26 Identifying Patients at Risk for Suicide: Brief Review (NEW)

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 27 Strategies To Prevent Stress-Related Gastrointestinal Bleeding (Stress Ulcer Prophylaxis): Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 28 Prevention of Venous Thromboembolism: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 29 Preventing Patient Death or Serious Injury Associated With Radiation Exposure from Fluoroscopy and Computed Tomography: Brief Review (NEW)

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 30 Ensuring Documentation of Patients' Preferences for Life-Sustaining Treatment: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 31 Human Factors and Ergonomics

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 32 Promoting Engagement by Patients and Families To Reduce Adverse Events (NEW)

Table 1, Chapter 32 Evidence table: patients engagement

Table 2, Chapter 32 Evidence table: patient's engagement, risk of bias

## Evidence Tables for Chapter 33 Promoting a Culture of Safety

Table 1, Chapter 33 Patient safety culture: evidence table

## Evidence Tables for Chapter 34 Effect of Nurse-to-Patient Staffing Ratios on Patient Morbidity and Mortality

Table 1, Chapter 34 Evidence table

## Evidence Tables for Chapter 35 Patient Safety Practices Targeted at Diagnostic Errors (NEW)

Table 1, Chapter 35 Evidence table

Table 2, Chapter 35 Summary of randomized trials

## Evidence Tables for Chapter 36 Monitoring Patient Safety Problems (NEW)

The layout of this evidence table is customized based on the data reported by the included studies. Some columns in the evidence tables for other PSP topics are not included in this table or merged with other columns. For example, the “Description of Organization” column is merged into the “Context” column. There is no “Theory or Logic Model” column in this table because none of the included studies reported such data. The customized layout allows the data collected to fit into the table appropriately.

Table 1, Chapter 36 Evidence from studies comparing methods for detecting patient safety problems

## Evidence Tables for Chapter 37 Interventions To Improve Care Transitions at Hospital Discharge (NEW)

Table 1, Chapter 37 Included studies and interventions

Table 2, Chapter 37 Study quality criteria

Table 3, Chapter 37 Included studies and outcomes

Table 4, Chapter 37 Studies reporting 30-day readmissions

Table 5, Chapter 37 Studies reporting adverse events (including adverse drug events)

## Evidence Tables for Chapter 38 Use of Simulation Exercises in Patient Safety Efforts

This review had no additional evidence tables.

## Evidence Tables for Chapter 39 Obtaining Informed Consent From Patients: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 40 Team-Training in Health Care: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 41 Computerized Provider Order Entry With Clinical Decision Support Systems: Brief Update Review

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 42 Tubing Misconnections: Brief Review (NEW)

This brief review had no additional evidence tables.

## Evidence Tables for Chapter 43 Limiting Individual Provider's Hours of Service: Brief Update Review

This brief review had no additional evidence tables.