# Abbreviations/Acronyms

AAGBI: Association of Anaesthetists of Great Britain and Ireland
AANA: American Association of Nurse Anesthetists
AAPM: American Association of Physicists in Medicine
ACCP: American College of Chest Physicians
ACGME: Accreditation Council for Graduate Medical Education
ACR: American College of Radiology
ACS NSQIP: American College of Surgeons National Surgical Quality Improvement Project
ADE: Adverse Drug Event
ADL: Activities of Daily Living
ADR: Adverse Drug Reaction
AE: Adverse Event
AHRQ: Agency for Healthcare Research and Quality
AIR: American Institute for Research
AMI: Acute Myocardial Infarction
AMSTAR: A measurement tool to assess systematic reviews
AORN: Association of periOperative Registered Nurses
APN: Advanced Practice Nurses
APOE4: Apolipoprotein E4
ARRA: American Recovery and Reinvestment
ASA: American Society of Anesthesiologists
ASATT: American Society of Anesthesia Technicians and Technologists
ASRT: American Society of Radiologic Technologists
AV: Audio/Video
BATS: Brain Attack Teams
BC/BS: Blue Cross/Blue Shield
BG: Blood Glucose
BIS: Bispectral Index
BMI: Body Mass Index
BPMH: Best Possible Medication History
BPOC: Barcode-Enabled Point of Care
C: Comparator
CAN-NSQIP: Canadian National Surgical Quality Improvement Collaborative
CAUTI: Catheter-Associated Urinary Tract Infections
cc: Milliliter
CCAs: Critical Care Areas
CCOT: Critical Care Outreach Team
CCT: Clinical Controlled Trial
CCTA: Cardiac Computed Tomography Angiography
CCU: Coronary Care Unit
CDC: Centers for Disease Control
CDC HICPAC: Centers for Disease Control and Prevention Healthcare Infection Control Practices Advisory Committee
CDSS: Clinical Decision Support Systems
CHF: Congestive Heart Failure
CHG: Chlorhexidine
CI: Confidence Interval
CI-AKI: Contrast-induced Acute Kidney Injury
CKD: Chronic Kidney Disease
CLABSI: Central Line-Associated Bloodstream Infections
CMS: Centers for Medicare & Medicaid Services
CNA: Certified Nursing Assistant
CNS: Clinical Nurse Specialist
CPOE: Computerized Provider Order Entry
CPRS: Computerized Patient Record System
CPSI: Canadian Patient Safety Institute
CRBSI: Catheter-related Bloodstream Infection
CRCPD: Conference of Radiation Control Program Directors
CRM: Crew Resource Management
CSO: Constant Special Observation
CSRS: Cardiac Surgery Reporting System
CSS: Computerized Surveillance System
CT: Computed Tomography
CTA: Computed Tomography Angiography
CTI: Care Transitions Intervention
CTPA: Computed Tomographic Pulmonary Angiography
CTSQC: Connecticut Surgical Quality Coalition
CUSP: Comprehensive Unit Based Safety Program
CVA: Cerebrovascular Accident
CVC: Central Venous Catheters
CWOCN: Certified Wound Ostomy Continence Nurse
DEER: Diagnostic Error Evaluation and Research
DERS: Dose Error Reduction System
DM: Diabetes Mellitus
DNR: Do Not Resuscitate
DoD: Department of Defense
DRG: Diagnosis-Related Group
DVT: Deep Venous Thrombosis
EAST: Eastern Association for the Surgery of Trauma
EBA: European Board of Anesthesiology
EBP: Evidence-based Practices
ED: Emergency Department
eMARs: Electronic Medication Administration Records
EMR: Electronic Medical Record
EPC: Evidence-Based Practice Center
EPOC: Effective Practice and Organization of Care
ESA: European Society of Anesthesiology
FDA: Food and Drug Administration
FHA: Florida Hospital Association
FMEA: Failure Mode and Effects Analysis
FPTK: Fall Prevention Tool Kit
FSCI: Florida Surgical Care Initiative
FTE: Full Time Employment
FTE: Full-time Equivalent
GAO: Government Accountability Office
GI: Gastrointestinal
GRAM: Geriatric Risk Assessment Medguide
HAI: Hospital-associated Infections
HAPU: Hospital-acquired Pressure Ulcer
HAT: Heart Attack Team
HELP: Hospital Elder Life Program
HFE: Human Factors and Ergonomics
HFMEA: Healthcare Failure Mode and Effects Analysis
HH: Hand Hygiene
HICPAC: Healthcare Infection Control Practices Advisory Committee
HITEC: Health Information Technology for Economic and Clinical Health
HR: Hazard Ratio
HS: At Bedtime
HSOPS: Hospital Survey on Patient Safety
ICDSC: Intensive Care Delirium Screening Checklist
ICU: Intensive Care Unit
IEA: International Ergonomics Association
IHI: Institute for Healthcare Improvement
IIDs: Intelligent Infusion Devices
IIT: Intensive Insulin Therapy
INR: International Normalized Ratio
IOM: Institute of Medicine
IOCM: Iso-osmolar Contrast Media
ISMP: Institute for Safe Medication Practices
ISQIC: Illinois Surgical Quality Improvement Collaborative
IT: Information Technology
IV: Intravenous
JC: Joint Commission
JCAHO: Joint Commission on Accreditation of Healthcare Organizations
KPNCRNC: Kaiser Permanente Northern California Regional NSQIP Collaborative
kV: Kilovolts
LEB: Lower Extremity Bypass
LEP: Limited English Proficiency
LMWH: Low Molecular Weight Heparins
LVN: Licensed Vocational Nurses
MCR: Manual Chart Review
MCSQC: Mayo Clinic Surgical Quality Consortium
MDS: Minimum Data Set
MET: Medical Emergency Team
MHCS: Making Health Care Safer
MICU: Medical Intensive Care Unit
MRSA: Methicillin-Resistant Staphylococcus Aureus
mSv: Millisievert
MS: Morphine Sulfate
MTT: Medical Team Training
NAAL: National Assessment of Adult Literacy
NAC: N-acetylcysteine
NCHS: National Center for Health Statistics
NCSQC: Northern California Surgical Quality Collaborative
NGC: National Guideline Clearinghouse
NHSN: National Healthcare Safety Network
NPSA: National Patient Safety Agency
NPSG: National Patient Safety Goal
NPUAP: National Pressure Ulcer Advisory Panel
NQF: National Quality Forum
NR: Not Reported
NS: Not Statistically Significant
NSAIDs: Non-steroidal Anti-inflammatory Drugs
NVASRS: National VA Surgical Risk Study
OEMs: Original Equipment Manufacturers
OR: Operating Room
OR: Odds Ratio
OSATS: Observed Structured Assessment of Technical Skills
PAC: Pre-Anesthesia Checkout
PACS: Picture Archiving and Communication Systems
PAE: Potential Adverse Event
PCA: Patient-Controlled Analgesia
PDA: Personal Digital Assistant
PDSA: Plan-Do-Study-Act
PE: Pulmonary Embolism
PGY: Post-graduate Year
PICC: Peripherally Inserted Central Catheters
POLST: Physician Orders for Life-Sustaining Treatment
PPACA: Patient Protection and Affordable Care Act
PPV: Positive Predictive Value
ProFaNE: Prevention of Falls Network Europe
PSC: Patient Safety Culture
PSCHO: Patient Safety Climate in Healthcare Organizations
PSP(s): Patient Safety Practice(s)
PTT: Partial Thromboplastin Time
PU: Pressure Ulcer
QA: Quality Assurance
QD: Once Daily
QI: Quality Improvement
QM: Quality Measures
QS: Quality System
RCA: Root Cause Analysis
RCT: Randomized Controlled Trial
RED: ReEngineered Discharge Program
RFID: Radio-frequency Identification
RN: Registered Nurse
RR: Relative Risk
RR: Rate Ratio
RRS: Rapid Response System
RRT: Renal Replacement Therapy
RSNA: Radiological Society of North America
SAQ: Safety Attitudes Questionnaire
SCHA: The South Carolina Hospital Association
SCIP: Surgical Care Improvement Project
SCOAP: Surgical Care and Outcome Assessment Program
SCR: Surgical Clinical Reviewer
SCS: Safety Climate Scale
SHEA: Society for Healthcare Epidemiology of America
SHS: Summa Health System
SICU: Surgical Intensive Care Unit
SMD: Standardized Mean Difference
SQAN: Surgical Quality Action Network
SSI: Sliding Scale Insulin
STS: Society of Thoracic Surgery
SUD: Single-Use Devices
SURPASS: SURgical PAtient Safety System
T: Treatment
TBD: To Be Determined
TCPS: Tennessee Center for Patient Safety
TEP: Technical Expert Panel
TIA: Transient Ischemic Attack
TIW: Three Times A Week
TSA: Team Situation Awarness
TSQC: Tennessee Surgical Quality Collaborative
TURP: Transurethral Resection of the Prostate
U: Units
U.K.: United Kingdom
U.S.: United States
UCSF: University of California, San Francisco
UHC: University Health System Consortium
UP: Universal Protocol
VA: Veterans Affairs
VAP: Ventilator Associated Pneumonia
VRE: Vancomycin-Resistant Enterococci
VRSA: Vancomycin-Resistant S. Aureus
VTBI: Volume-To-Be-Infused
VTE: Venous Thromboembolism
WHO: World Health Organization
WOCN: Wound, Ostomy and Continence Nurses Society
WON: Wound Ostomy Nurse