# References

1 Balsells M, Garcia-Patterson A, Gich I, et al. Maternal and fetal outcome in women with type 2 versus type 1 diabetes mellitus: a systematic review and metaanalysis. J Clin Endocrinol Metab. 2009;94(11):4284-91. [pmid: 19808847].
2 National Diabetes Data Group. Diabetes in America. 2nd ed. Bethesda, MD. National Institutes of Health. 1995.
3 HAPO Study Cooperative Research Group, Metzger B, Lowe L, et al. Hyperglycemia and Adverse Pregnancy Outcomes. N Engl J Med. 2008;358(19):1991-2002. [pmid: 18463375].
4 American Diabetes Association. Position statement: standards of medical care in diabetes - 2012. Diabetes Care. 2012;35(Suppl 1):S11-S63. [pmid: 22187469].
5 Carpenter MW, Coustan DR. Criteria for screening tests for gestational diabetes. Am J Obstet Gynecol. 1982;144(7):768-73. [pmid: 7148898].
6 Sacks DA, Hadden DR, Maresh M, et al. Frequency of gestational diabetes mellitus at collaborating centers based on IADPSG consensus panel-recommended criteria: the Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. Diabetes Care. 2012;35(3):526-8. [pmid: 22355019].
7 Ferrara A. Increasing prevalence of gestational diabetes mellitus: a public health perspective. Diabetes Care. Suppl 2. 2007;30:S141-S146. [pmid: 17596462].
8 Mokdad AH, Ford ES, Bowman BA, et al. Prevalence of obesity, diabetes, and obesity-related health risk factors, 2001. JAMA. 2003;289(1):76-9. [pmid: 12503980].
9 Gillman MW, Oakey H, Baghurst PA, et al. Effect of treatment of gestational diabetes mellitus on obesity in the next generation. Diabetes Care. 2010;33(5):964-8. [pmid: 20150300].
10 Kaufmann RC, Schleyhahn FT, Huffman DG, et al. Gestational diabetes diagnostic criteria: long-term maternal follow-up. Am J Obstet Gynecol. 1995;172(2 Pt 1):621-5. [pmid: 7856695].
11 Mokdad AH, Ford ES, Bowman BA, et al. Diabetes trends in the U.S.: 1990-1998. Diabetes Care. 2000;23(9):1278-83. [pmid: 10977060].
12 Mokdad AH, Serdula MK, Dietz WH, et al. The spread of the obesity epidemic in the United States, 1991-1998. JAMA. 1999;282(16):1519-22. [pmid: 10546690].
13 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2006;29(Suppl 1):S43-S48. [pmid: 16373932].
14 Berger H, Crane J, Farine D, et al. Screening for gestational diabetes mellitus. J Obstet Gynaecol Can. 2002;24(11):894-912. [pmid: 12417905].
15 Naylor CD, Sermer M, Chen E, et al. Selective screening for gestational diabetes mellitus. Toronto Trihospital Gestational Diabetes Project Investigators. N Engl J Med. 1997;337(22):1591-6. [pmid: 9371855].
16 Hillier T, Vesco K, Pedula K, et al. Screening for gestational diabetes mellitus: A systematic review for the U.S. preventive services task force. Ann Intern Med. 2008;148:766-75. [pmid: 18490689].
17 American College of Obstetricians and Gynecologists Committee on Practice Bulletins. ACOG Practice Bulletin. Clinical management guidelines for obstetrician-gynecologists. Number 30, September 2001. Gestational Diabetes. Obstet Gynecol. 2001;98(3):525-38. [pmid: 11547793].
18 Meltzer SJ, Snyder J, Penrod JR, et al. Gestational diabetes mellitus screening and diagnosis: a prospective randomised controlled trial comparing costs of one-step and two-step methods. BJOG. 2010;117(4):407-15. [pmid: 20105163].
19 Gabbe S, Gregory R, Power M, et al. Management of diabetes mellitus by obstetrician-gynecologists. Obstet Gynecol. 2004;103(6):1229-34. [pmid: 15172857].
20 American Diabetes Association. Position Statement: Diabetes mellitus. Diabetes Care. 2004;27(Suppl 1):S11-S14. [pmid: 14693922].
21 Moses RG, Cheung NW. Point: Universal screening for gestational diabetes mellitus. Diabetes Care. 2009;32(7):1349-51. [pmid: 19564479].
22 Danilenko-Dixon DR, Van Winter JT, Nelson RL, et al. Universal versus selective gestational diabetes screening: application of 1997 American Diabetes Association recommendations. Am J Obstet Gynecol. 1999;181(4):798-802. [pmid: 10521732].
23 Berger H, Sermer M. Counterpoint: Selective screening for gestational diabetes mellitus. Diabetes Care. 2009;32(7):1352-4. [pmid: 19564480].
24 Metzger B, Gabbe S, Persson B, et al. International association of diabetes and pregnancy study groups recommendations on the diagnosis and classification of hyperglycemia in pregnancy. Diabetes Care. 2010;33(3):676-82. [pmid: 20190296].
25 Lipscombe LL, Hux JE. Trends in diabetes prevalence, incidence, and mortality in Ontario, Canada 1995-2005: a population-based study. Lancet. 2007;369(9563):750-6. [pmid: 17336651].
26 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 1999;22(Suppl 1):S5-S19.
27 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2000;23(Suppl 1):S4-S19. [pmid: 12017675].
28 Report of the expert committee on the diagnosis and classification of diabetes mellitus. Diabetes Care. 2001;24(Suppl.1):S5-S20.
29 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2002;25:S5.
30 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2003;26:S5-20. [pmid: 12502614].
31 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2004;27(Suppl 1):S5-S10. [pmid: 14693921].
32 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2005;28(Suppl 1):S37-S42. [pmid: 15618111].
33 American Diabetes Association. Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2007;30(Suppl 1):S42-S7. [pmid: 17192378].
34 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2008;31:S55-S60. [pmid: 18165338].
35 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2009;32:S62-S67. [pmid: 19118289].
36 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2010;33:S62-S69. [pmid: 20042775].
37 International association of diabetes and pregnancy study groups recommendations on the diagnosis and classification of hyperglycemia in pregnancy. Diabetes Care. 2010;33(3):676-82. [pmid: 20190296].
38 Jovanovic L. American Diabetes Association's Fourth International Workshop-Conference on Gestational Diabetes Mellitus: summary and discussion. Therapeutic interventions. Diabetes Care. Suppl 2. 1998;21:B131-B137. [pmid: 9704240].
39 Metzger BE, Oats JN, Kjos SL, et al. Summary and Recommendations of the Fifth International Workshop-Conference on Gestational Diabetes Mellitus. Diabetes Care. 2007;30(Suppl 2):s251-s260. [pmid: 17596481].
40 Classification and diagnosis of diabetes mellitus and other categories of glucose intolerance. National Diabetes Data Group. Diabetes. 1979;28(12):1039-57. [pmid: 510803].
41 World Health Organization, Definition, diagnosis and classification of diabetes mellitus and its complications. Report of a WHO Consultation. Part 1: Diagnosis and classification of diabetes mellitus. 1999.
42 World Health Organization. Report of a WHO study Group (Technical Report Series No.727). Report of a WHO study Group (Technical Report Series No.727). 1985.
43 Canadian Diabetes Association Clinical Practice Guidelines Expert Committee. Canadian Diabetes Association 2003 Clinical Practice Guidelines for the Prevention and Management of Diabetes in Canada. Can J Diabetes. 2003;27(suppl 2):S1-S152.
44 Canadian Diabetes Association 2008 Clinical Practice Guidelines for the Prevention and Management of Diabetes in Canada [corrected]. [published erratum appears in CAN J DIABETES 2009 Mar;33(1):46]. Canadian Journal of Diabetes. 2008;32:iv.
45 Sempowski IP, Houlden RL. Managing diabetes during pregnancy. Guide for family physicians. Canadian Family Physician Médecin De Famille Canadien. 2003;49:761-7. [pmid: 12836864].
46 Metzger BE. Summary and recommendations of the Third International Workshop-Conference on Gestational Diabetes Mellitus. Diabetes. Suppl 2. 1991;40:197-201. [pmid: 1748259].
47 Hoffman L, Nolan C, Wilson JD, et al. Gestational diabetes mellitus--management guidelines. The Australasian Diabetes in Pregnancy Society. The Medical Journal Of Australia. 1998;169(2):93-7. [pmid: 9700346].
48 Brown CJ, Dawson A, Dodds R, et al. Report of the Pregnancy and Neonatal Care Group. Diabetic Medicine: A Journal Of The British Diabetic Association. 1996;13(9 Suppl 4):S43-S53. [pmid: 8894455].
49 American Diabetes Association. Position statement: Gestational diabetes mellitus. Diabetes Care. 2003;26(Suppl 1):S103-S105. [pmid: 12502631].
50 Crowther CA, Hiller JE, Moss JR, et al. Effect of treatment of gestational diabetes mellitus on pregnancy outcomes. N Engl J Med. 2005;352(24):2477-86. [pmid: 15951574].
51 Langer O, Levy J, Brustman L, et al. Glycemic control in gestational diabetes mellitus--how tight is tight enough: small for gestational age versus large for gestational age?. Am J Obstet Gynecol. 1989;161(3):646-53. [pmid: 2782347].
52 Cheung NW, Oats JJ, McIntyre HD. Australian carbohydrate intolerance study in pregnant women: implications for the management of gestational diabetes. Aust N Z J Obstet Gynaecol. 2005;45(6):484-5. [pmid: 16401212].
53 U.S.Preventive Services Task Force. Screening for gestational diabetes mellitus: recommendations and rationale. Obstet Gynecol. 2003;101(2):393-395. [pmid: 12576265].
54 Landon MB, Spong CY, Thom E, et al. A multicenter, randomized trial of treatment for mild gestational diabetes. N Engl J Med. 2009;361(14):1339-48. [pmid: 19797280].
55 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
56 Rutter C, Gastonis C. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Stat Med. 2001;20:2865-84. [pmid: 11568945].
57 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58(10):982-90. [pmid: 16168343].
58 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
59 Borenstein M, Hedges L, Higgins J, et al. Introduction to meta-analysis. West Sussex, UK. John Wiley & Sons. 2009.
60 Begg C, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50:1088-101. [pmid: 7786990].
61 Egger M, Smith G, Schneider M, et al. Bias in meta-analysis detected by a single graphical test. Br Med J. 1997;315(629):634. [pmid: 9310563].
62 van LM, Zweers EJ, Opmeer BC, et al. Comparison of accuracy measures of two screening tests for gestational diabetes mellitus. Diabetes Care. 2007;30(11):2779-84. [pmid: 17698616].
63 Ayach W, Costa RA, Calderon IM, et al. Comparison between 100-g glucose tolerance test and two other screening tests for gestational diabetes: combined fasting glucose with risk factors and 50-g glucose tolerance test. Rev Paul Med. 2006;124(1):4-9. [pmid: 16612455].
64 Yogev Y, Langer O, Xenakis EM, et al. Glucose screening in Mexican-American women. Obstet Gynecol. 2004;103(6):1241-5. [pmid: 15172859].
65 Chastang N, Hartemann-Heurtier A, Sachon C, et al. Comparison of two diagnostic tests for gestational diabetes in predicting macrosomia. Diabetes Metab. 2003;29(2 Pt 1):139-44. [pmid: 12746634].
66 Perea-Carrasco R, Perez-Coronel R, busac-Aguilar R, et al. A simple index for detection of gestational diabetes mellitus. J R Soc Med. 2002;95(9):435-9. [pmid: 12205206].
67 Ardawi MS, Nasrat HA, Jamal HS, et al. Screening for gestational diabetes mellitus in pregnant females. Saudi Med J. 2000;21(2):155-60. [pmid: 11533772].
68 Perucchini D, Fischer U, Spinas GA, et al. Using fasting plasma glucose concentrations to screen for gestational diabetes mellitus: prospective population based study. BMJ: British Medical Journal (International Edition). 1999;319(7213):812-5. [pmid: 10496823].
69 Lamar ME, Kuehl TJ, Cooney AT, et al. Jelly beans as an alternative to a fifty-gram glucose beverage for gestational diabetes screening. Am J Obstet Gynecol. 1999;181(5 Pt 1):1154-7. [pmid: 10561636].
70 Siribaddana SH, Deshabandu R, Rajapakse D, et al. The prevalence of gestational diabetes in a Sri Lankan antenatal clinic. Ceylon Med J. 1998;43(2):88-91. [pmid: 9704548].
71 Eslamian L, Ramezani Z. Evaluation of a breakfast as screening test for the detection of gestational diabetes. Acta Medica Iranica. 2008;46(1):43-6.
72 Espinosa De, Los MA, Parra A, Hidalgo R, et al. The after breakfast 50-g, 1-hour glucose challenge test in urban Mexican pregnant women: Its sensitivity and specificity evaluated by three diagnostic criteria for gestational diabetes mellitus. Acta Obstet Gynecol Scand. 1999;78(4):294-8. [pmid: 10203295].
73 Deerochanawong C, Putiyanun C, Wongsuryrat M, et al. Comparison of National Diabetes Data Group and World Health Organization criteria for detecting gestational diabetes mellitus. Diabetologia. 1996;39(9):1070-3. [pmid: 8877291].
74 Uncu G, Ozan H, Cengiz C. The comparison of 50 grams glucose challenge test, HbA(1c) and fructosamine levels in diagnosis of gestational diabetes mellitus. Clin Exp Obstet Gynecol. 1995;22(3):230-4. [pmid: 7554262].
75 Kashi Z, Borzouei SH, Akha O, et al. Diagnostic value of fasting plasma glucose in screening of gestational diabetes mellitus. Int J Endocrinol Metab. 2007;5(1):1-4.
76 Gandevani SB, Garshasbi A, Dibaj S. Cut-off value of 1-h, 50-g glucose challenge test for screening of gestational diabetes mellitus in an Iranian population. J Obstet Gynaecol Res. 2011;37(6):534-7. [pmid: 21375670].
77 Soheilykhah S, Rashidi M, Mojibian M, et al. An appropriate test for diagnosis of gestational diabetes mellitus. Gynecol Endocrinol. 2011;27(10):785-8. [pmid: 21250875].
78 Black MH, Sacks DA, Xiang AH, et al. Clinical outcomes of pregnancies complicated by mild gestational diabetes mellitus differ by combinations of abnormal oral glucose tolerance test values. Diabetes Care. 2010;33(12):2524-30. [pmid: 20843973].
79 Morikawa M, Yamada T, Yamada T, et al. Change in the number of patients after the adoption of IADPSG criteria for hyperglycemia during pregnancy in Japanese women. Diabetes Res Clin Pract. 2010;90(3):339-42. [pmid: 20870307].
80 Corrado F, Benedetto AD, Cannata ML, et al. A single abnormal value of the glucose tolerance test is related to increased adverse perinatal outcome. J Matern Fetal Neonatal Med. 2009;22(7):597-601. [pmid: 19488948].
81 Cheng YW, Block-Kurbisch I, Caughey AB. Carpenter-Coustan criteria compared with the national diabetes data group thresholds for gestational diabetes mellitus. Obstet Gynecol. 2009;114(2:Pt 1):326-32. [pmid: 19622994].
82 Biri A, Korucuoglu U, Ozcan P, et al. Effect of different degrees of glucose intolerance on maternal and perinatal outcomes. J Matern Fetal Neonatal Med. 2009;22(6):473-8. [pmid: 19479645].
83 Retnakaran R, Qi Y, Sermer M, et al. Glucose intolerance in pregnancy and future risk of pre-diabetes or diabetes. Diabetes Care. 2008;31(10):2026-31. [pmid: 18628572].
84 Shirazian N, Mahboubi M, Emdadi R, et al. Comparison of different diagnostic criteria for gestational diabetes mellitus based on the 75-g oral glucose tolerance test: a cohort study. Endocrine Pract. 2008;14(3):312-7. [pmid: 18463038].
85 Kwik M, Seeho SK, Smith C, et al. Outcomes of pregnancies affected by impaired glucose tolerance. Diabetes Res Clin Pract. 2007;77(2):263-8. [pmid: 17275121].
86 Chico A, Lopez-Rodo V, Rodriguez-Vaca D, et al. Features and outcome of pregnancies complicated by impaired glucose tolerance and gestational diabetes diagnosed using different criteria in a Spanish population. Diabetes Res Clin Pract. 2005;68(2):141-6. [pmid: 15860242].
87 Bo S, Menato G, Gallo ML, et al. Mild gestational hyperglycemia, the metabolic syndrome and adverse neonatal outcomes. Acta Obstet Gynecol Scand. 2004;83(4):335-40. [pmid: 15005779].
88 Stamilio DM, Olsen T, Ratcliffe S, et al. False-positive 1-hour glucose challenge test and adverse perinatal outcomes. Obstet Gynecol. 2004;103(1):148-56. [pmid: 14704259].
89 Pennison EH, Egerman RS. Perinatal outcomes in gestational diabetes: a comparison of criteria for diagnosis. Am J Obstet Gynecol. 2001;184(6):1118-21. [pmid: 11349174].
90 Berggren EK, Boggess KA, Stuebe AM, et al. National Diabetes Data Group vs. Carpenter-Coustan criteria to diagnose gestational diabetes. Am J Obstet Gynecol. 2011;205(3):253-e1-7. [pmid: 22071053].
91 Sacks DA, Greenspoon JS, bu-Fadil S, et al. Toward universal criteria for gestational diabetes: The 75-gram glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1995;172(2 I):607-14. [pmid: 7856693].
92 Chou C, Lin C, Yang C, et al. Pregnancy outcomes of Taiwanese women with gestational diabetes mellitus: a comparison of Carpenter-Coustan and National Diabetes Data Group criteria. J Womens Health. 2010;19(5):935-8. [pmid: 20370431].
93 Lapolla A, Dalfra MG, Ragazzi E, et al. New International Association of the Diabetes and Pregnancy Study Groups (IADPSG) recommendations for diagnosing gestational diabetes compared with former criteria: a retrospective study on pregnancy outcome. Diabetic Med. 2011;28(9):1074-7. [pmid: 21658125].
94 Cok T, Tarim E, Bagis T. Isolated abnormal value during the 3-hour glucose tolerance test: which value is associated with macrosomia?. J Matern Fetal Neonatal Med. 2011;24(8):1039-41. [pmid: 21247232].
95 Fassett MJ, Dhillon SH, Williams TR. Effects on perinatal outcome of treating women with 1 elevated glucose tolerance test value. Am J Obstet Gynecol. 2007;196(6):597.e1-4. [pmid: 17547912].
96 Malcolm JC, Lawson ML, Gaboury I, et al. Glucose tolerance of offspring of mother with gestational diabetes mellitus in a low-risk population. Diabetic Med. 2006;23(5):565-70. [pmid: 16681566].
97 Bonomo M, Corica D, Mion E, et al. Evaluating the therapeutic approach in pregnancies complicated by borderline glucose intolerance: a randomized clinical trial. Diabetic Med. 2005;22(11):1536-41. [pmid: 16241919].
98 Bevier WC, Fischer R, Jovanovic L. Treatment of women with an abnormal glucose challenge test (but a normal oral glucose tolerance test) decreases the prevalence of macrosomia. Am J Perinatol. 1999;16(6):269-75. [pmid: 10586979].
99 Agarwal MM, Hughes PF, Punnose J, et al. Fasting plasma glucose as a screening test for gestational diabetes in a multi-ethnic, high-risk population. Diabet Med. 2000;17(10):720-6. [pmid: 11110505].
100 Agarwal MM, Hughes PF, Punnose J, et al. Gestational diabetes screening of a multiethnic, high-risk population using glycated proteins. Diabetes Research and Clinical Practice. 2001;51(1):67-73. [pmid: 11137184].
101 Maegawa Y, Sugiyama T, Kusaka H, et al. Screening tests for gestational diabetes in Japan in the 1st and 2nd trimester of pregnancy. Diabetes Research and Clinical Practice. 2003;62(1):47-53. [pmid: 14581157].
102 Ricart W, Lopez J, Mozas J, et al. Potential impact of American Diabetes Association (2000) criteria for diagnosis of gestational diabetes mellitus in Spain. Diabetologia. 2005;48(6):1135-41. [pmid: 15889233].
103 Kim HS, Chang KH, Yang JI, et al. Clinical outcomes of pregnancy with one elevated glucose tolerance test value. Int J Gynaecol Obstet. 2002;78(2):131-8. [pmid: 12175714].
104 Bobrowski RA, Bottoms SF, Micallef JA, et al. Is the 50-gram glucose screening test ever diagnostic?. J Matern Fetal Med. 1996;5(6):317-20. [pmid: 8972407].
105 Rey E, Hudon L, Michon N, et al. Fasting plasma glucose versus glucose challenge test: screening for gestational diabetes and cost effectiveness. Clin Biochem. 2004;37(9):780-4. [pmid: 15329316].
106 Vambergue A, Nuttens MC, Verier-Mine O, et al. Is mild gestational hyperglycaemia associated with maternal and neonatal complications? The Diagest Study. Diabet Med. 2000;17(3):203-8. [pmid: 10784224].
107 Rajput R, yadav Yogesh, Rajput M, et al. Utility of HbA(1c) for diagnosis of gestational diabetes mellitus. Diabetes Res Clin Pract. 2012. [pmid: 22456454].
108 Chevalier N, Fenichel P, Giaume V, et al. Universal two-step screening strategy for gestational diabetes has weak relevance in French Mediterranean women: should we simplify the screening strategy for gestational diabetes in France?. Diabetes Metab. 2011;37(5):419-25. [pmid: 21489844].
109 Agarwal MM, Dhatt GS, Othman Y, et al. Gestational diabetes: an evaluation of serum fructosamine as a screening test in a high-risk population. Gynecol Obstet Invest. 2011;71(3):207-12. [pmid: 21160150].
110 Agarwal MM, Dhatt GS, Safraou MF. Gestational diabetes: using a portable glucometer to simplify the approach to screening. Gynecol Obstet Invest. 2008;66(3):178-83. [pmid: 18562798].
111 Wijeyaratne CN, Ginige S, Arasalingam A, et al. Screening for gestational diabetes mellitus: the Sri Lankan experience. Ceylon Med J. 2006;51(2):53-8. [pmid: 17180809].
112 Agarwal MM, Dhatt GS, Punnose J. Gestational diabetes: utility of fasting plasma glucose as a screening test depends on the diagnostic criteria. Diabetic Med. 2006;23(12):1319-26. [pmid: 17116182].
113 Agarwal MM, Dhatt GS, Punnose J, et al. Gestational diabetes: a reappraisal of HBA1c as a screening test. Acta Obstet Gynecol Scand. 2005;84(12):1159-63. [pmid: 16305701].
114 Hill JC, Krishnaveni GV, Annamma I, et al. Glucose tolerance in pregnancy in South India: relationships to neonatal anthropometry. Acta Obstet Gynecol Scand. 2005;84(2):159-65. [pmid: 15683377].
115 Jensen DM, Molsted-Pedersen L, Beck-Nielsen H, et al. Screening for gestational diabetes mellitus by a model based on risk indicators: a prospective study. Am J Obstet Gynecol. 2003;189(5):1383-8. [pmid: 14634573].
116 Buhling KJ, Henrich W, Kjos SL, et al. Comparison of point-of-care-testing glucose meters with standard laboratory measurement of the 50g-glucose-challenge test (GCT) during pregnancy. Clin Biochem. 2003;36(5):333-7. [pmid: 12849863].
117 Jakobi P, Weissman A, Egozi J, et al. Perinatal significance of diagnosing glucose intolerance during pregnancy with portable glucose meter. J Perinat Med. 2003;31(2):140-5. [pmid: 12747230].
118 Soonthornpun S, Soonthornpun K, Aksonteing J, et al. A comparison between a 75-g and 100-g oral glucose tolerance test in pregnant women. Int J Gynaecol Obstet. 2003;81(2):169-73. [pmid: 12706274].
119 Ostlund I, Hanson U. Occurrence of gestational diabetes mellitus and the value of different screening indicators for the oral glucose tolerance test. Acta Obstet Gynecol Scand. 2003;82(2):103-8. [pmid: 12648169].
120 Reichelt AJ, Spichler ER, Branchtein L, et al. Fasting plasma glucose is a useful test for the detection of gestational diabetes. Brazilian Study of Gestational Diabetes (EBDG) Working Group. Diabetes Care. 1998;21(8):1246-9. [pmid: 9702428].
121 Rust O, Bofill JA, Carroll SC, et al. Two-hour postprandial test versus one-hour, fifty-gram glucola test as screening tools for gestational diabetes: a critical analysis. J Perinatol. 1998;18(1):49-54. [pmid: 9527945].
122 Fung HY, Wong SP, Rogers M. The influence of glucose tolerance tests on subsequent carbohydrate metabolism in pregnancy. Acta Obstet Gynecol Scand. 1996;75(4):347-51. [pmid: 8638454].
123 Berkus MD, Langer O. Glucose tolerance test periodicity: the effect of glucose loading. Obstet Gynecol. 1995;85(3):423-7. [pmid: 7862384].
124 Moses RG, Morris GJ, Petocz P, et al. The impact of potential new diagnostic criteria on the prevalence of gestational diabetes mellitus in Australia. The Medical Journal Of Australia. 2011;194(7):338-40. [pmid: 21470082].
125 Buhling KJ, Elze L, Henrich W, et al. The usefulness of glycosuria and the influence of maternal blood pressure in screening for gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 2004;113(2):145-8. [pmid: 15063950].
126 Sacks DA, Chen W, Wolde-Tsadik G, et al. Fasting plasma glucose test at the first prenatal visit as a screen for gestational diabetes. Obstet Gynecol. 2003;101(6):1197-203. [pmid: 12798525].
127 Kauffman RP, Castracane VD, Peghee D, et al. Detection of gestational diabetes mellitus by homeostatic indices of insulin sensitivity: A preliminary study. Am J Obstet Gynecol. 2006;194(6):1576-82. [pmid: 16638603].
128 Balaji V, Madhuri BS, Paneerselvam A, et al. Comparison of Venous Plasma Glucose and Capillary Whole Blood Glucose in the Diagnosis of Gestational Diabetes Mellitus: A Community-Based Study. Diabetes Technol Ther. 2011;14(2):131-4. [pmid: 21992269].
129 Balaji V, Balaji M, Anjalakshi C, et al. Inadequacy of fasting plasma glucose to diagnose gestational diabetes mellitus in Asian Indian women. Diabetes Res Clin Pract. 2011;94(1):e21-e23. [pmid: 21831468].
130 Chanprapaph P, Sutjarit C. Prevalence of gestational diabetes mellitus (GDM) in women screened by glucose challenge test (GCT) at Maharaj Nakorn Chiang Mai Hospital. J Med Assoc Thai. 2004;87(10):1141-6. [pmid: 15560687].
131 Solomon CG, Willett WC, Rich-Edwards J, et al. Variability in diagnostic evaluation and criteria for gestational diabetes. Diabetes Care. 1996;19(1):12-6. [pmid: 8720526].
132 Hillier TA, Pedula KL, Schmidt MM, et al. Childhood obesity and metabolic imprinting: the ongoing effects of maternal hyperglycemia. Diabetes Care. 2007;30(9):2287-92. [pmid: 17519427].
133 Jensen DM, Damm P, Sorensen B, et al. Proposed diagnostic thresholds for gestational diabetes mellitus according to a 75-g oral glucose tolerance test. Maternal and perinatal outcomes in 3260 Danish women. Diabetic Med. 2003;20(1):51-7. [pmid: 12519320].
134 Lao TT, Tam KF. Gestational diabetes diagnosed in third trimester pregnancy and pregnancy outcome. Acta Obstet Gynecol Scand. 2001;80(11):1003-8. [pmid: 11703196].
135 Rust OA, Bofill JA, Andrew ME, et al. Lowering the threshold for the diagnosis of gestational diabetes. Am J Obstet Gynecol. 1996;175(4 Pt 1):961-5. [pmid: 8885755].
136 Berkus MD, Langer O, Piper JM, et al. Efficiency of lower threshold criteria for the diagnosis of gestational diabetes. Obstet Gynecol. 1995;86(6):892-6. [pmid: 7501334].
137 Tan PC, Ling LP, Omar SZ. The 50-g glucose challenge test and pregnancy outcome in a multiethnic Asian population at high risk for gestational diabetes. Int J Gynaecol Obstet. 2009;105(1):50-5. [pmid: 19154997].
138 Agarwal MM, Dhatt GS, Punnose J, et al. Gestational diabetes in a high-risk population: using the fasting plasma glucose to simplify the diagnostic algorithm. Eur J Obstet Gynecol Reprod Biol. 2005;120(1):39-44. [pmid: 15866084].
139 Yachi Y, Tanaka Y, Anasako Y, et al. Contribution of first trimester fasting plasma insulin levels to the incidence of glucose intolerance in later pregnancy: Tanaka women's clinic study. Diabetes Res Clin Pract. 2011;92(2):293-8. [pmid: 21396732].
140 Weerakiet S, Lertnarkorn K, Panburana P, et al. Can adiponectin predict gestational diabetes?. Gynecol Endocrinol. 2006;22(7):362-8. [pmid: 16864145].
141 Bito T, Nyari T, Kovacs L, et al. Oral glucose tolerance testing at gestational weeks < or =16 could predict or exclude subsequent gestational diabetes mellitus during the current pregnancy in high risk group. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):51-5. [pmid: 15989984].
142 Sermer M, Naylor CD, Gare DJ, et al. Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1995;173(1):146-56. [pmid: 7631672].
143 Brustman LE, Gela BD, Moore M, et al. Variations in oral glucose tolerance tests: the 100- versus 75-g controversy. J Assoc Acad Minor Phys. 1995;6(2):70-2. [pmid: 7772935].
144 Cetin M, Cetin A. Time-dependent gestational diabetes screening values. Int J Gynecol Obstet. 1997;56(3):257-61. [pmid: 9127158].
145 Lapolla A, Dalfra MG, Bonomo M, et al. Can plasma glucose and HbA1c predict fetal growth in mothers with different glucose tolerance levels?. Diabetes Res Clin Pract. 2007;77(3):465-70. [pmid: 17350135].
146 Langer O, Yogev Y, Most O, et al. Gestational diabetes: the consequences of not treating. Am J Obstet Gynecol. 2005;192(4):989-97. [pmid: 15846171].
147 Lao TT, Ho LF. Does maternal glucose intolerance affect the length of gestation in singleton pregnancies?. J Soc Gynecol Investig. 2003;10(6):366-71. [pmid: 12969780].
148 Bonomo M, Gandini ML, Farina A, et al. Should we treat minor degrees of glucose intolerance in pregnancy?. Ann Ist Super Sanita. 1997;33(3):393-7. [pmid: 9542269].
149 Nord E, Hanson U, Persson B. Blood glucose limits in the diagnosis of impaired glucose tolerance during pregnancy. Relation to morbidity. Acta Obstet Gynecol Scand. 1995;74(8):589-93. [pmid: 7660761].
150 Schwartz ML, Ray WN, Lubarsky SL, et al. The diagnosis and classification of gestational diabetes mellitus: Is it time to change our tune?. Am J Obstet Gynecol. 1999;180(6 I):1560-71. [pmid: 10368504].
151 Poyhonen-Alho MK, Teramo KA, Kaaja RJ, et al. 50gram oral glucose challenge test combined with risk factor-based screening for gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):34-7. [pmid: 15989983].
152 Adams KM, Li H, Nelson RL, et al. Sequelae of unrecognized gestational diabetes. Am J Obstet Gynecol. 1998;178(6):1321-32. [pmid: 9662318].
153 Mello G, Elena P, Ognibene A, et al. Lack of concordance between the 75-g and 100-g glucose load tests for the diagnosis of gestational diabetes mellitus. Clin Chem. 2006;52(9):1679-84. [pmid: 16873295].
154 Aberg A, Rydhstroem H, Frid A. Impaired glucose tolerance associated with adverse pregnancy outcome: a population-based study in southern. Sweden Am J Obstet Gynecol. 2001;184(2):77-83. [pmid: 11174484].
155 Yang X, Hsu-Hage B, Zhang H, et al. Women with impaired glucose tolerance during pregnancy have significantly poor pregnancy outcomes. Diabetes Care. 2002;25(9):1619-24. [pmid: 12196437].
156 Sun B, Wang X, Song Q, et al. Prospective studies on the relationship between the 50 g glucose challenge test and pregnant outcome. Chin Med J. 1995;108(12):910-3. [pmid: 8728943].
157 Tan PC, Ling LP, Omar SZ. Screening for gestational diabetes at antenatal booking in a Malaysian university hospital: the role of risk factors and threshold value for the 50-g glucose challenge test. Aust N Z J Obstet Gynaecol. 2007;47(3):191-7. [pmid: 17550485].
158 O'Sullivan JB, Mahan CM. Criteria for the oral glucose tolerance test in pregnancy. Diabetes. 1964;13:278-85. [pmid: 14166677].
159 Sermer M, Naylor CD, Farine D, et al. The Toronto Tri-Hospital Gestational Diabetes Project. A preliminary review. Diabetes Care. 1998;21(Suppl 2):B33-B42. [pmid: 9704225].
160 Naylor CD, Sermer M, Chen E, et al. Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Trihospital Gestational Diabetes Investigators. JAMA. 1996;275(15):1165-70. [pmid: 8609683].
161 Eslamian L, Ramezani Z. Breakfast as a screening test for gestational diabetes. Int J Gynaecol Obstet. 2007;96(1):34-5. [pmid: 17188692].
162 van LM, Opmeer BC, Zweers EJ, et al. Estimating the risk of gestational diabetes mellitus: a clinical prediction model based on patient characteristics and medical history. BJOG. 2010;117(1):69-75. [pmid: 20002371].
163 Landon MB, Mele L, Spong CY, et al. The relationship between maternal glycemia and perinatal outcome. Obstet Gynecol. 2011;117(2 Pt 1):218-24. [pmid: 21309194].
164 Pirc LK, Owens JA, Crowther CA, et al. Mild gestational diabetes in pregnancy and the adipoinsular axis in babies born to mothers in the ACHOIS randomised controlled trial. BMC Pediatr. 2007;7:18. [pmid: 17430602].
165 Rasmussen SS, Glumer C, Sandbaek A, et al. Short-term reproducibility of impaired fasting glycaemia, impaired glucose tolerance and diabetes The ADDITION study, DK. Diabetes Res Clin Pract. 2008;80(1):146-52. [pmid: 18082284].
166 Hyperglycemia and adverse pregnency outcome (HAPO) study Cooperative Research Group. Hyperglycemia and adverse pregnancy outcomes. The New England Journal of Medicine. 2008;358(19):1991-2002. [pmid: 18463375].
167 Naylor CD, Sermer M, Chen EL, et al. Selective screening for gestational diabetes mellitus. N Engl J Med. 1997;337(22):1591-6. [pmid: 9371855].
168 Phillips DI. Programming of the stress response: a fundamental mechanism underlying the long-term effects of the fetal environment?. J Intern Med. 2007;261(5):453-60. [pmid: 17444884].
169 Daniells S, Grenyer BFS, Davis WS, et al. Gestational diabetes mellitus: Is a diagnosis associated with an increase in maternal anxiety and stress in the short and intermediate term?. Diabetes Care. 2003;26(2):385-9. [pmid: 12547867].
170 Horvath K, Koch K, Jeitler K, et al. Effects of treatment in women with gestational diabetes mellitus: systematic review and meta-analysis. BMJ: British Medical Journal (International Edition). 2010;340:c1395. [pmid: 20360215].
171 Pettitt DJ, McKenna S, McLaughlin C, et al. Maternal glucose at 28 weeks of gestation is not associated with obesity in 2-year-old offspring: The Belfast Hyperglycemia and Adverse Pregnancy Outcome (HAPO) family study. Diabetes Care. 2010;33(6):1219-23. [pmid: 20215449].
172 Ryan EA. Diagnosing gestational diabetes. Diabetologia. 2011;54(3):480-6. [pmid: 21203743].
173 HAPO Study Cooperative Research Group. Hyperglycaemia and Adverse Pregnancy Outcome (HAPO) Study: associations with maternal body mass index. BJOG. 2010;117(5):575-84. [pmid: 20089115].
174 Ricart W, Lopez J, Mozas J, et al. Body mass index has a greater impact on pregnancy outcomes than gestational hyperglycaemia. Diabetologia. 2005;48(9):1736-42. [pmid: 16052327].
175 Cundy T, Gamble G, Townend K, et al. Perinatal mortality in Type 2 diabetes mellitus. Diabet Med. 2000;17(1):33-9. [pmid: 10691157].
176 Schaefer-Graf UM, Hartmann R, Pawliczak J, et al. Association of breast-feeding and early childhood overweight in children from mothers with gestational diabetes mellitus. Diabetes Care. 2006;29(5):1105-7. [pmid: 16644645].
177 Buchanan TA, Kjos SL, Montoro MN, et al. Use of fetal ultrasound to select metabolic therapy for pregnancies complicated by mild gestational diabetes. Diabetes Care. 1994;17(4):275-83. [pmid: 8026282].