# Introduction

## Gestational Diabetes Mellitus

Gestational diabetes mellitus (GDM) is defined as glucose intolerance first discovered in pregnancy. Pregestational diabetes refers to any type of diabetes diagnosed before pregnancy. Pregnant women with pregestational diabetes experience an increased risk of poor maternal, fetal and neonatal outcomes.1 The extent to which GDM predicts adverse outcomes for mother, fetus and neonate is less clear.

Depending on the diagnostic criteria used and the population screened, the prevalence of GDM ranges from 1.1 to 25.5 percent of pregnancies in the United States.2-4 In 2009 the Centers for Disease Control and Prevention reported a prevalence of 4.8 percent of diabetes in pregnancy. An estimated 0.5 percent of these cases likely represented women with pregestational diabetes. Data from the international Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study3 indicate that 6.7 percent of the women met a fasting plasma glucose threshold of 95 mg/dL (5.3 mmol/L), which is in keeping with the Carpenter and Coustan5 (CC) criteria that are in common practice in North America. In contrast, 17.8 percent of women were diagnosed with GDM using the International Association of Diabetes in Pregnancy Study Groups (IADPSG) criteria in which lower glucose thresholds are proposed to diagnose GDM.

The prevalence of GDM is not only influenced by diagnostic criteria but also by population characteristics. In a recent publication, data from the HAPO study demonstrate wide variability in GDM prevalence across a variety of study centers internationally and within the United States, even when the same diagnostic criteria are applied (i.e., IADPSG).6 Prevalence in the United States ranged from 15.5 percent in Providence, RI, to 25.5 percent in Bellflower, CA. There are ethnic differences in the prevalence of GDM in the United States. Native American, Asian, Hispanic, and African-American women are at higher risk than non-Hispanic white women based on CC criteria and/or hospital discharge diagnosis.7 Data from 2000 showed that prevalence was highest among Asian and Hispanic women (∼7 to 8 percent), intermediate among African-American women (∼6 percent), and lower among non-Hispanic white women (∼5 percent). The rate of increase of prevalence over the past 10 years has been highest for Asian and African-American women. A report from Montana demonstrated that the prevalence of GDM increased by approximately 10 percent among white women and by approximately 21 percent among Native American women from 2000 to 2003.^7^

The incidence of GDM has increased over the past decades in parallel with the increase in rates of obesity and type 2 diabetes mellitus, and this trend is expected to continue. In 2001 in the United States, the prevalence of obesity (body mass index [BMI] ≥30) was 20.9 percent and the prevalence of diabetes was 7.9 percent.8 It is unclear how much the increase in obesity will impact the proportion of women diagnosed with overt diabetes during pregnancy versus transient pregnancy induced glucose intolerance.9

GDM is usually diagnosed after 20 weeks' gestation when placental hormones that have the opposite effect of insulin on glucose metabolism increase substantially. Women with adequate insulin secreting capacity overcome this insulin resistance of pregnancy by secreting more endogenous insulin in order to maintain normal blood glucose. Women with less adequate pancreatic reserve are unable to produce adequate insulin to overcome the increase in insulin resistance, and glucose intolerance results.

Glucose abnormalities in women with GDM usually resolve postpartum, but commonly recur in subsequent pregnancies. Women with GDM have an increased risk of future development of overt diabetes. The cumulative incidence of diabetes after a diagnosis of GDM varies widely depending on maternal BMI, ethnicity, and time since index pregnancy, and may reach levels as high as 60 percent.10 When glucose abnormalities persist postpartum in a woman with GDM, her diabetes is recategorized as overt diabetes. When this occurs, the possibility that this woman had pregestational (i.e., overt) diabetes increases, especially if the diagnosis of GDM occurred prior to 20 weeks' gestation and glucose levels were markedly elevated in pregnancy.

The increased rates of obesity and type 2 diabetes mellitus, particularly among young females, makes it increasingly important to distinguish the effect of obesity and pregestational diabetes from GDM.11,12 There is considerable variability in the proportion of women with suspected pregestational diabetes among studies that investigate pregnancy outcomes of women with GDM. This contributes to the confusion surrounding the true morbidity of GDM. In an attempt to enable better comparability across future studies and more accurate risk stratification of pregnant women with diabetes, recommendations13 have proposed the exclusion of women with more severe glucose abnormalities in pregnancy from the diagnosis of GDM in an attempt to exclude women with pregestational (i.e., overt diabetes) from the population of women defined as having GDM. This proposal is in contrast to the older definition of GDM as any degree of glucose intolerance first discovered in pregnancy.

### Risk Factors

Risk factors for GDM include greater maternal age, higher BMI, member of an ethnic group at increased risk for development of type 2 diabetes mellitus (i.e., Hispanic, African, Native American, South or East Asian, or Pacific Inlands ancestry), polyhydramnios, past history of GDM, macrosomia in a previous pregnancy, history of unexplained stillbirth, type 2 diabetes mellitus in a first degree relative, polycystic ovary syndrome, and metabolic syndrome.14 Low risk of GDM is usually defined as young (age less than 25 or 30 years), non-Hispanic white, normal BMI (25 kg/m^2^ or less), no history of previous glucose intolerance or adverse pregnancy outcomes associated with GDM, and no first degree relative with known diabetes.7,15 Women at high risk of GDM are usually defined as having multiple risk factors for GDM. Women at moderate risk of GDM do not satisfy all criteria of women at low risk, but they lack two or more risks for GDM.

### Screening and Diagnostic Strategies

The 2008 U.S. Preventive Services Task Force (USPSTF) evidence review on screening for GDM concluded that, at that time, “evidence was insufficient to assess the balance of benefits and harms of screening for gestational diabetes mellitus either before or after 24 weeks' gestation.”16 The report suggested that “…until there was better evidence clinicians should discuss screening for GDM with their patient and make case-by-case decisions. Discussions should include information about the uncertainty of benefits and harm as well as the frequency of positive screening test results.”

The 2001 practice guidelines of the American College of Obstetricians and Gynecologists (ACOG) endorsed risk factor-based screening for GDM, recognizing that low risk women may be less likely to benefit from screening with glucose measurements. Women were considered low risk of GDM if they met all the following criteria: (1) younger than 25 years; (2) not a member of an ethnic group at high risk for development of type 2 diabetes mellitus; (3) BMI of 25 kg/m^2^ or less; (4) no history of previous glucose intolerance or adverse pregnancy outcomes associated with GDM; and (5) no first degree relative with known diabetes. AGOG will update their 2001 practice guidelines on GDM based on the proceedings of the 2012 National Institutes of Health consensus conference on GDM diagnosis. Until 2011 the American Diabetes Association (ADA) also endorsed no screening for pregnant woman who met all the criteria mentioned above for low risk of GDM. In 2011 the ADA changed their recommendations to endorse glucose testing for GDM in all pregnant women who do not have a diagnosis of pregestational diabetes.

Common practices of glucose screening for GDM in North America involve a two-step approach in which patients with abnormal results on a screening test receive a subsequent diagnostic test.17 Typically, a 50 g oral glucose challenge test (OGCT) is initially administered between 24 and 28 weeks' gestation in a nonfasting state, in women at moderate risk (i.e., women who do not meet all low risk criteria but lack two or more risk factors for GDM). The test is administered earlier in gestation for women at high risk of GDM (i.e., multiple risk factors for GDM) and repeated at 24-28 weeks' gestation if initial surveillance is normal. Patients who meet or exceed a screening threshold (usually 130 mg/dL or 140 mg/dL) receive a more involved diagnostic test, the oral glucose tolerance test (OGTT) in which a 75 g or 100 g oral glucose load is administered in a fasting state, and plasma glucose levels are evaluated after 1, 2, or 3 hours. A diagnosis of GDM is made in pregnant women when one or more glucose values fall at or above the specified glucose thresholds. Alternatively, a one-step method in which all patients or high risk patients forego the screening test and proceed directly to the OGTT has been recommended.18 Interest has grown in assessing the usefulness of fasting plasma glucose as an alternative to the OGCT for screening for GDM for a number of reasons. First, the IADPG has proposed the use of a high threshold fasting plasma glucose 126 mg/dL (7.0 mmol/L) as soon as pregnancy is confirmed in women at high risk of type 2 diabetes mellitus as a means of identifying women with overt diabetes that likely predates their pregnancy. It is hypothesized that lesser degrees of fasting glucose elevation could be used to screen for GDM if this test is already being done to rule out overt diabetes. However, fasting glucose in early pregnancy is not well studied. Second, the reproducibility of fasting glucose measurement is superior to post glucose load measurements.149 Third, some women do not tolerate the oral glucose drinks.

The absence of a universally accepted “gold standard” for the diagnosis of GDM has resulted in a variety of recommended diagnostic glucose thresholds that have been endorsed by different stakeholders (Table 1; Figure 1). These criteria reflect changes that have occurred in laboratory glucose measurements over the years, and new evidence that suggests the ability of different glucose thresholds to predict poor pregnancy outcomes. The different diagnostic criteria and thresholds result in different estimates of prevalence of GDM.

Table 1 Diagnostic criteria and plasma glucose thresholds for GDM

Organization | Year | Testing Schedule | Abnormal Value(s) | Threshold (Equal to or Greater Than)
Organization | Year | Testing Schedule | Abnormal Value(s) | 0 (h) | 1 (h) | 2 (h) | 3 (h)
ADA | 1999^26^ | 50 g OGCT | 1 | — | 140 mg/dL 7.8 mmol/L | — | —
ADA | 1999^26^ | 100 g OGTT | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
ADA Low risk^†^ excluded | 2000-2010^13,27-36^ | 50 g OGCT | 1 | — | 130 mg/dL 7.2 mmol/L or 140 mg/dL 7.8 mmol/L | — | —
ADA Low risk^†^ excluded | 2000-2010^13,27-36^ | 100 g or 75 g OGTT after overnight fast ≥8 hr | 2 or more | 95 mg/dL 5.3 mmol/L | 180 mg/dL 10.0 mmol/L | 155 mg/dL 8.6 mmol/L | 140 mg/dL 7.8 mmol/L (3 hr value only for 100-g test)
IADPSG ADA | 2011-2012^37^ | 75 g OGTT | 1 or more | 92 mg/dL 5.1 mmol/L | 180 mg/dL 10.0 mmol/L | 153 mg/dL 8.5 mmol/L | —
1. CC; 2. 4^th^ IWC (same); 3. 5^th^ IWC (same as 4^th^ but 75 g accepted with same glucose thresholds) | 1. 1982^5^; 2. 1998^38^; 3. 2007^39^ | 50 g OGCT | 1 | — | 130 mg/dL 7.2 mmol/L | — | —
1. CC; 2. 4^th^ IWC (same); 3. 5^th^ IWC (same as 4^th^ but 75 g accepted with same glucose thresholds) | 1. 1982^5^; 2. 1998^38^; 3. 2007^39^ | 100 g OGTT | 2 or more | 95 mg/dL 5.3 mmol/L | 180 mg/dL 10.0 mmol/L | 155 mg/dL 8.6 mmol/L | 140 mg/dL 7.8 mmol/L
NDDG | 1979^40^ | 50 g OGCT | — | — | — | — | —
NDDG | 1979^40^ | 100 g OGTT | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
WHO | 1999 WHO consultation41 | 75 g OGTT | 1 | 6.1 mmol/L for IGT of pregnancy; 7.0 mmol/L for Dx of DM | — | 140 mg/dL 7.8 mmol/L for IGT of pregnancy; 200 mg/dL 11.1 mmol/L for Dx of DM | —
WHO | 1985 WHO study group report42 | 75 g OGTT | 1 | 7.8 mmol/L 140 mg/dL for IGT of pregnancy | — | 7.8 mmol/L (140 mg/dL); for IGT of pregnancy; 200 (11.1 mmol/L) for Dx of DM | —
CDA | 2003, 2008^43,44^ | 50 g OGCT | 1 | — | 140 mg/dL 7.8 mmol/L or 186 mg/dL, 10.3 mmol/L Dx GDM | — | —
CDA | 2003, 2008^43,44^ | 75 g | 2 or more | 95 mg/dL 5.3 mmol/L | 191 mg/dL 10.6 mmol/L | 160 mg/dL 8.9 mmol/L | —
ACOG – risk factor 4^th^ IWC | 2001^17,45^ | 50 g | 1 | — | 130 mg/dL 7.2 mmol/L or 140 mg/dL 7.8 mmol/L | — | —
ACOG – risk factor 4^th^ IWC | 2001^17,45^ | 100 g CC | 2 or more | 95 mg/dL 5.3 mmol/L | 180 mg/dL 10.0 mmol/L | 155 mg/dL 8.5 mmol/L | 140 mg/dL 7.8 mmol/L
ACOG – risk factor 4^th^ IWC | 2001^17,45^ | 100 g NDDG | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
3^rd^ IWC | 1991^46^ | 100 g OGTT | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
ADIPS | 1998^47^ | 50 g or 75 g nonfasting | 1 | — | 140 mg/dL 7.8 mmol/L (50 g) or 144 mg/dL 8.0 mmol/L (75 g) | — | —
ADIPS | 1998^47^ | 75 g fasting | 1 | 99 mg/dL 5.5 mmol/L | — | 144 mg/dL 8.0 mmol/L or 1 62 mg/dL 9.0 mmol/L^*^ | —
EASD | 1996^48^ | 75 g | 1 | 108 mg/dL 6.0 mmol/L | — | 162 mg/dL 9.0 mmol/L | —
USPSTF (Grade 1 recommendation) | 2008^‡^ | Risk Assessment 50 g OGCT | 1 | — | 130 mg/dL 7.2 mmol/L or 140 mg/dL 7.8 mmol/L | — | —
USPSTF (Grade 1 recommendation) | 2008^‡^ | 100 g OGTT | 2 or more | NR | NR | NR | NR

ACOG = American College of Obstetricians and Gynecologists, ADA = American Diabetes Association, ADIPS = Australasian Diabetes in Pregnancy Society, CC = Carpenter, Coustan, CDA = Canadian Diabetes Association, DM = diabetes mellitus, Dx = diagnosis, EASD = European Association for the Study of Diabetes, h = hours; IADPSG = International Association of Diabetes in Pregnancy Study Groups, IGT = impaired glucose tolerance, IWC = International Workshop Conference, NDDG = National Diabetes Data Group, NR = not reported, OGCT = oral glucose challenge test, OGTT = oral glucose tolerance test, USPSTF = U.S. Preventive Services Task Force, WHO = World Health Organization

† Low risk defined as: (1) age <25 yr, (2) normal body weight, (3) no first degree relative with DM, (4) no history of abnormal glucose, (5) no history of poor obstetrical outcomes, (6) not of high-risk ethnicity for DM.

* In New Zealand.

‡ Screening for gestational diabetes mellitus: U.S. Preventive Services Task Force recommendation statement. Annals of Internal Medicine 2008;148(10):759-65.

Figure 1 Comparison of different diagnostic thresholds for GDM

ADA = American Diabetes Association, CC = Carpenter-Coustan, CDA = Canadian Diabetes Association, dL= deciliter, g = grams, IADPSG = International Association of Diabetes in Pregnancy Study Groups, L= liter; mg = milligrams, mmol = millimoles; NDDG = National Diabetes Data Group, WHO = World Health Organization

Note: This figure presents the various diagnostic criteria for GDM. The top bar compares fasting glucose diagnostic thresholds. The bottom bar compares post glucose load diagnostic thresholds. The criteria are arranged from left (green) to right (red) from the lowest diagnostic glucose thresholds to the highest. The post glucose load bar is not entirely comparable because different glucose loads were used as indicated. The bottom part of each box shows which diagnostic thresholds were accepted by various organizations over the years including any modifications to the criteria. For example, ADA 2000 to 2010 endorsed the CC diagnostic thresholds on a 75g or 100g OGTT.

Figure 1 is a pictorial comparison of fasting thresholds and post glucose thresholds among IADPSG, CC, NDDG, and WHO criteria. The top bar compares fasting glucose thresholds in both milligrams per deciliter and millimoles per liter. When reading from left to right, it starts with the lowest diagnostic glucose threshold IADPSG criteria, followed by CC criteria, NDDG criteria, and ending with the highest diagnostic glucose threshold WHO criteria. The bottom bar compares post glucose load thresholds across criteria, with both milligrams per deciliter and millimoles per liter. When reading from left to right, it starts with the lowest diagnostic glucose threshold WHO criteria, followed by IADPSG criteria, CC criteria, and ending with the highest diagnostic glucose thresholds, NDDG criteria.

In 2004, a cross-sectional study reported that universal screening was the most common practice in the United States with 96 percent of obstetricians routinely screening for GDM.19 In contrast, the guidelines of ACOG and the ADA at that time stated that women at low risk for GDM were unlikely to benefit from screening.17,20 Since only 10 percent of pregnant women were categorized as low risk, some argued that selective screening contributed to confusion with little benefit and potential for harm.21 Of particular concern was the association between risk factor-based screening and high rates of false negative results.22 Others have endorsed alternative risk scoring systems for screening.23

The IADPSG, an international consensus group with representation from multiple obstetrical and diabetes organizations, recently spearheaded a re-examination of the definition of GDM in an attempt to bring uniformity to GDM diagnoses.24 The IADPSG recommended that a one-step 75 g OGTT be given to all pregnant women who do not have a diagnosis of overt diabetes. They also recommended that a single glucose value, rather than at least two abnormal values at or above diagnostic glucose thresholds on the OGTT be accepted as sufficient for a diagnosis of GDM. The diagnostic glucose thresholds recommended by the IADPSG were the maternal glucose values from the HAPO study3 that identified a 1.75-fold increase (adjusted odds ratio relative to the mean cohort glucose values) in large for gestational age, elevated C-peptide, high neonatal body fat, or a combination of these factors. Since overt diabetes is often asymptomatic, may not have been screened for prior to conception, has a prevalence that is increasing dramatically in reproductive age women, and carries a higher risk for poor pregnancy outcomes, the IADPSG also recommended that all or at least women from high risk groups for type 2 diabetes mellitus be screened for overt diabetes at their first prenatal visit and excluded from the diagnosis of GDM using one of the following criteria: fasting plasma glucose ≥126 mg/dL (7.0 mmol/L), glycated hemoglobin (HbA1c) ≥6.5 percent (Diabetes Chronic Complications Trial/United Kingdom Prospective Diabetes Study standardized), or a random plasma glucose ≥200 mg/dL (11.1 mmol/L) confirmed by one of the first two measures.25

### Treatment Strategies

Initial treatment for GDM involves diet modification, glucose monitoring, and moderate exercise. When dietary management does not achieve desired glucose control, insulin or oral antidiabetic medications may be used.49 Increased prenatal surveillance may also occur as well as changes in delivery management depending on fetal size and the effectiveness of measures to control glucose.

The 2008 USPSTF report found that treatment of women with mild GDM (excluding women who met World Health Organization criteria for overt diabetes) diagnosed after 24 weeks' gestation provided benefits in terms of maternal and neonatal health outcomes.16 Specifically, they found evidence from a high quality trial involving 1,000 women showing a reduction in “any serious perinatal complication” which included death, shoulder dystocia, bone fracture, and nerve palsy.50 The number of events for many of the individual outcomes was extremely small, which did not provide adequate evidence to make conclusions for individual outcomes. The same study showed a reduction in maternal hypertension.50 Further, among a subset of survey respondents, mothers who received treatment were less depressed at 3 months and data showed a trend to better quality of life compared with women who did not receive treatment.50

The USPSTF report found no evidence of harms of treatment, although the available evidence was sparse and the review authors observed that these events may be rare and may not be observed in trials.16 Potential harms of treatment may include small for gestational age neonates, maternal stress, and additional costs including those associated with laboratory testing as well as patient and clinician time.51 Clinician time can include the physician as well as diabetes educators, nutritionists, and other providers of obstetrical care. Healthcare provider anxiety over the diagnosis of GDM is a potential harm that could result in additional, and possibly unnecessary or overly aggressive, fetal, and neonatal surveillance and delivery management. Evidence suggests that the label of GDM, regardless of need, appears to influence the care provided as evidenced by higher neonatal intensive care unit admission rates for the newborn babies of women treated for GDM.52

## Scope and Key Questions

### Scope of the Review

Based on systematic reviews published in 2003 and 2008, the USPSTF concluded that there was insufficient evidence upon which to make a recommendation regarding routine screening of all pregnant women for gestational diabetes.16,53 However, several key studies have been published since the 2008 report.3,9,54 The National Institutes of Health Office of Medical Applications of Research (OMAR) commissioned this report (Key Questions 3 to 5, see section below) and it was conducted by the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) Program. OMAR will use the review to inform a consensus meeting and guideline development. The USPSTF joined this effort and will use the review to update its recommendation on screening for GDM (Key Questions 1 and 2 below).

The primary aims of this review were to: (1) identify the test properties of screening and diagnostic tests for GDM, (2) evaluate the potential benefits and harms of screening at ≥24 weeks and <24 weeks' gestation,(3) assess the impact of different screening and diagnostic thresholds on outcomes for mothers and their offspring, and (4) determine the effects of treatment in modifying outcomes for women diagnosed with GDM. The benefits and harms of treatments will be considered in this review in order to determine the downstream effects of screening on health outcomes. The intent of this review was also to assess whether evidence gaps of the previous USPSTF reviews have been filled. These gaps included lack of sufficient evidence to determine whether maternal or fetal complications are reduced by screening; lack of screening studies with adequate power to evaluate health outcomes such as mortality, NICU admissions, hyperbilirubinemia; limited evidence on the accuracy of screening strategies; and insufficient evidence on the benefits of treating GDM in improving health outcomes.

### Key Questions

The Key Questions for this evidence synthesis were developed by OMAR and the USPSTF to inform consensus meetings and guideline development (OMAR specifically developed Key Questions 3 to 5). Investigators from the University of Alberta EPC worked in consultation with representatives from AHRQ, OMAR and the USPSTF, and a panel of technical experts to operationalize the Key Questions. The technical expert panel provided content and methodological expertise throughout the development of this evidence synthesis. Participants of this panel are identified in the front matter of this report. The Key Questions are as follows:

Key Question 1 What are the sensitivities, specificities, reliabilities, and yields of current screening tests for GDM? (a) After 24 weeks' gestation? (b) During the first trimester and up to 24 weeks' gestation?
  - Population: Pregnant women (≥24 weeks' gestation and <24 weeks' gestation) without known preexisting diabetes mellitus (DM)
  - Interventions: Any screening or diagnostic test, including one-step, two-step, or other approach
  - Comparators: Any reference standard
  - Outcomes: Sensitivity, specificity, positive predictive value, negative predictive value, reliability (i.e., accuracy), and yield (i.e., prevalence)
  - Timing: Any duration of followup
  - Settings: All settings
Key Question 2 What is the direct evidence on the benefits and harms of screening women (before and after 24 weeks' gestation) for GDM to reduce maternal, fetal, and infant morbidity and mortality?
  - Population: Pregnant women (≥24 weeks' gestation and <24 weeks' gestation) without known preexisting DM
  - Interventions: Any screening or diagnostic test, including one-step, two-step, or other approach; if diagnosed with GDM, any treatment
  - Comparators: No test for GDM
  - Outcomes: Maternal, fetal, and infant morbidity and mortality
  - Timing: Any duration of followup
  - Settings: All settings
Key Question 3 In the absence of treatment, how do health outcomes of mothers who meet various criteria for GDM and their offspring compare to those who do not meet the various criteria?
  - Population: Pregnant women (≥24 weeks' gestation and <24 weeks' gestation) without known preexisting DM who meet different test thresholds for GDM
  - Interventions: None
  - Comparators: Pregnant women (≥24 weeks' gestation and <24 weeks' gestation) without known preexisting DM who do not meet specific test thresholds for GDM
  - Outcomes:
    ○ Maternal
      – Short-term: preeclampsia/maternal hypertension, cesarean delivery (elective and medically indicated), depression, birth trauma, mortality, weight gain
      – Long-term: type 2 DM risk, obesity, hypertension
    ○ Fetal/neonatal/child
      – Short-term: macrosomia, shoulder dystocia, clavicular fracture, brachial plexus injury (permanent and transient), birth injury, hypoglycemia, hyperbilirubinemia, mortality
      – Long-term: obesity, type 2 DM, transgenerational GDM
  - Timing: Any duration of followup
  - Settings: All settings
Key Question 4 Does treatment modify the health outcomes of mothers who meet various criteria for GDM and offspring?
  - Population: Pregnant women (≥24 weeks' gestation and <24 weeks' gestation) without known preexisting DM who meet any diagnostic threshold for GDM
  - Interventions: Any treatment for GDM including, but not limited to, dietary advice, blood glucose monitoring, insulin therapy, and oral hypoglycemic agents
  - Comparators: Placebo or no treatment
  - Outcomes:
    ○ Maternal
      – Short-term: preeclampsia/maternal hypertension, cesarean delivery (elective and medically indicated), depression, birth trauma, mortality, weight gain
      – Long-term: type 2 DM risk, obesity, hypertension
    ○ Fetal/neonatal/child
      – Short-term: macrosomia, shoulder dystocia, clavicular fracture, brachial plexus injury (permanent and transient), birth injury, hypoglycemia, hyperbilirubinemia, mortality
      – Long-term: obesity, type 2 DM, transgenerational GDM
  - Timing: Any duration of followup
  - Settings: All settings
Key Question 5 What are the harms of treating GDM and do they vary by diagnostic approach?
  - Population: Pregnant women (≥24 weeks' gestation and <24 weeks' gestation) without known preexisting DM who meet any diagnostic threshold for GDM
  - Interventions: Any treatment for GDM including, but not limited to, dietary advice, blood glucose monitoring, insulin therapy, and oral hypoglycemic agents
  - Comparators: Placebo or no treatment
  - Outcomes: Harms, including anxiety, healthcare system issues, burden on practitioner's office, increased interventions due to treatment bias (e.g., increased cesarean sections resulting from bias of caregivers toward expectation of adverse outcomes), postpartum depression, SGA, costs, and resource allocations
  - Timing: Any duration of followup
  - Settings: All settings

We developed an analytic framework (Figure 2) to describe the path from screening pregnant women to the potential benefits and harms of treatment. The figure illustrates the clinical concepts and mechanism by which screening and treatment for GDM may result in beneficial or adverse maternal and fetal/neonatal/child outcomes. The figure also indicates the relation between the Key Questions and the specific links along the pathway from screening to final outcome.

Figure 2 Analytic framework for screening and diagnosing GDM

Note: The circled numbers correspond to the Key Questions.

AE = adverse event, GDM = gestational diabetes mellitus

Figure 2 is an analytic framework depicting the process for screening and diagnosis of gestational diabetes. The framework provides information on the patient population of interest; the flow through screening, diagnosis and treatment, and the stages at which adverse events can occur; and short-term and long-term outcomes for both mother and offspring. The population of interest is pregnant women, ≥24 weeks' and <24 weeks' gestation, who undergo screening for gestational diabetes. Screening can result in short-term and long-term benefits for mother and offspring, as well as adverse effects. Women who are screened may or may not meet diagnostic criteria for gestational diabetes. Those meeting different thresholds for gestational diabetes may or may not undergo treatment. Treatment or lack of treatment may affect short-term and long-term health outcomes for mother and offspring. Treatment may also be associated with adverse effects. Maternal outcomes include: preeclampsia or maternal hypertension, cesarean delivery, depression, birth trauma, mortality, weight gain, type 2 diabetes mellitus, obesity, and hypertension. Fetal outcomes include: macrosomia, shoulder dystocia, clavicular fracture, brachial plexus injury, birth injury, hypoglycemia, hyperbilirubinemia, mortality, type 2 diabetes mellitus, obesity, and transgenerational GDM.