# Peer Reviewers

Florence Brown, M.D.

Assistant Professor, Harvard Medical School

Director, Joslin-Beth Israel Deaconess

Diabetes and Pregnancy Program

Boston, MA

William Callaghan, M.D., M.P.H.

Senior Scientist

Maternal and Infant Health Branch

Division of Reproductive Health

National Center for Chronic Disease

Prevention and Health Promotion

Atlanta, GA

Robert P. Kauffman, M.D.

Professor

Department of Obstetrics and Gynecology

Texas Tech University

Lubbock, TX

Hélène Long, M.D.

Endocrinologist

Cité de la Santé de Laval Hospital

Laval, QC, Canada

Julia Lowe, M.D.

Associate Professor, Endocrinology

University of Toronto, Sunnybrook Health Sciences Center

Toronto, ON, Canada

James Peter VanDorsten, M.D.

Professor

Department of Obstetrics and Gynecology

Medical University of South Carolina

Charleston, SC