# Technical Expert Panel

Howard Berger, M.D.

Assistant Professor

Health Policy, Management, and Evaluation

University of Toronto

Toronto, ON

Siri L. Kjos, M.D., M.S.Ed.

Clinical Faculty

David Geffen School of Medicine

University of California, Los Angeles

Torrance, CA

Joy Melnikow, M.D., M.P.H

Professor

Family and Community Medicine

University of California, Davis

Sacramento, CA

Wanda K. Nicholson, M.D., M.P.H., M.B.A.

Associate Professor

Obstetrics and Gynecology

University of North Carolina

Chapel Hill, NC

Leann Olansky, M.D.

Medical Director

Lennon Diabetes Center, Huron Hospital

Cleveland Clinic East

Cleveland, OH