# Executive Summary

## Introduction

### Gestational Diabetes Mellitus

Gestational diabetes mellitus (GDM) is defined as glucose intolerance first discovered in pregnancy. Pregestational diabetes mellitus refers to any type of diabetes diagnosed before pregnancy. Pregnant women with pregestational diabetes experience an increased risk of poor maternal, fetal, and neonatal outcomes.1 The extent to which GDM predicts adverse outcomes for mother, fetus, and neonate is less clear.

Depending on the diagnostic criteria used and the population screened, the prevalence of GDM ranges from 1.1 to 25.5 percent of pregnancies in the United States.2-4 In 2009, the Centers for Disease Control and Prevention reported a prevalence of 4.8 percent of diabetes in pregnancy. An estimated 0.5 percent of these cases likely represented women with pregestational diabetes. Data from the international Hyperglycemia and Adverse Pregnancy Outcome (HAPO) study3 indicate that 6.7 percent of the women met a fasting plasma glucose threshold of 95 mg/dL (5.3 mmol/L), which is in keeping with the Carpenter and Coustan5 (CC) criteria that are in common practice in North America. In contrast, 17.8 percent of women were diagnosed with GDM using the International Association of the Diabetes in Pregnancy Study Groups (IADPSG) criteria in which lower glucose thresholds diagnose GDM.

The prevalence of GDM is not only influenced by diagnostic criteria but also by population characteristics. In a recent publication, data from the Hyperglycemia and Adverse Pregnancy Outcome Study (HAPO) demonstrated wide variability in GDM prevalence across a number of study centers, both internationally and within the United States, even when the same diagnostic criteria are applied (i.e., the IADPSG criteria).6 Prevalence in the United States ranged from 15.5 percent in Providence, RI, to 25.5 percent in Bellflower, CA. There are ethnic differences in the prevalence of GDM in the United States. Native Americans, Asians, Hispanics, and African-American women are at higher risk than non-Hispanic white women.7 Data from 2000 showed that prevalence was highest among Asian and Hispanic women (∼7 to 8 percent), intermediate among African-American women (∼6 percent), and lower among non-Hispanic white women (∼5 percent) based on CC criteria and/or hospital discharge diagnosis.7 The rate of increase of prevalence over the past 10 years has been highest for Asian and African-American women.7

The incidence of GDM has increased over the past decades in parallel with the increase in rates of obesity and type 2 diabetes mellitus, and this trend is expected to continue.8 It is unclear how much the increase in obesity will affect the proportion of women diagnosed with overt diabetes during pregnancy versus transient pregnancy-induced glucose intolerance.

GDM is usually diagnosed after 20 weeks' gestation when placental hormones that have the opposite effect of insulin on glucose metabolism increase substantially. Women with adequate insulin secreting capacity overcome this insulin resistance of pregnancy by secreting more endogenous insulin to maintain normal blood glucose. Women with less adequate pancreatic reserve are unable to produce sufficient insulin to overcome the increase in insulin resistance, and glucose intolerance results.

Glucose abnormalities in women with GDM usually resolve postpartum, but commonly recur in subsequent pregnancies. Women with GDM have an increased risk of future development of overt diabetes. The cumulative incidence of diabetes after a diagnosis of GDM varies widely depending on maternal body mass index (BMI), ethnicity, and time since index pregnancy, and it may reach levels as high as 60 percent.9 When glucose abnormalities persist postpartum in a woman with GDM, her diabetes is recategorized as overt diabetes. When this occurs, the likelihood that this woman had pregestational (i.e., overt) diabetes increases, especially if the diagnosis of GDM occurred before 20 weeks' gestation and glucose levels were markedly elevated in pregnancy.

Studies investigating pregnancy outcomes of women with GDM show considerable variability in the proportion of women with suspected pregestational diabetes. This variability contributes to the confusion surrounding the true morbidity of GDM. In an attempt to enable better comparability across future studies and more accurate risk stratification of pregnant women with diabetes, recommendations10 have proposed that women with more severe glucose abnormalities in pregnancy be excluded from the diagnosis of GDM. The expectation is that this would exclude women with overt diabetes from the population of women defined as having GDM. This proposal is in contrast to the older definition of GDM, which includes any degree of glucose intolerance first discovered in pregnancy.

### Risk Factors

Risk factors for GDM include greater maternal age, higher BMI, member of an ethnic group at increased risk for development of type 2 diabetes mellitus (i.e., Hispanic, African, Native American, South or East Asian, or Pacific Islands ancestry), polyhydramnios, past history of GDM, macrosomia in a previous pregnancy, history of unexplained stillbirth, type 2 diabetes mellitus in a first degree relative, polycystic ovary syndrome, and metabolic syndrome.11 Low risk of GDM is usually defined as young (age less than 25 or 30 years), non-Hispanic white, normal BMI (25 kg/m^2^ or less), no history of previous glucose intolerance or adverse pregnancy outcomes associated with GDM, and no first degree relative with known diabetes.7,12 Women at high risk of GDM are usually defined as having two or more risk factors for GDM. Women at moderate risk of GDM do not satisfy all criteria of women at low risk, but they lack two or more risk factors for GDM.

### Screening and Diagnostic Strategies

The 2008 U.S. Preventive Services Task Force (USPSTF) evidence review on screening for GDM concluded that at that time, “evidence was insufficient to assess the balance of benefits and harms of screening for GDM either before or after 24 weeks' gestation.”13 The report suggested that “…until there was better evidence, clinicians should discuss screening for GDM with their patient and make case-by-case decisions. Discussions should include information about the uncertainty of benefits and harms as well as the frequency of positive screening test results.”

The 2001 practice guidelines of the American College of Obstetricians and Gynecologists (ACOG) endorsed risk factor-based screening for GDM, recognizing that low-risk women may be less likely to benefit from screening with glucose measurements. Women were considered low risk of GDM if they met all the following criteria: (1) younger than 25 years; (2) not a member of an ethnic group at high risk for development of type 2 diabetes mellitus; (3) BMI of 25 kg/m^2^ or less; (4) no history of previous glucose intolerance or adverse pregnancy outcomes associated with GDM; and (5) no first degree relative with known diabetes. ACOG plans to update its 2001 practice guidelines on GDM based on the proceedings of the 2012 National Institutes of Health consensus conference on GDM diagnosis. Until 2011, the American Diabetes Association (ADA) also endorsed no screening for pregnant woman who met all the criteria mentioned above for low risk of GDM. In 2011 the ADA changed their recommendations to endorse glucose testing for GDM in all pregnant women who do not have a diagnosis of pregestational diabetes.

Common practices of glucose screening for GDM in North America involve a two-step approach in which patients with abnormal results on a screening test receive a subsequent diagnostic test.14 Typically, a 50 g oral glucose challenge test (OGCT) is initially administered between 24 and 28 weeks' gestation in a nonfasting state, in women at moderate risk (i.e., women who do not meet all low risk criteria but lack two or more risk factors for GDM). The test is administered earlier in gestation for women at high risk of GDM (i.e., multiple risk factors for GDM) and repeated at 24–28 weeks' gestation if initial surveillance is normal. Patients who meet or exceed a screening threshold (usually 130 mg/dL or 140 mg/dL) receive a more involved diagnostic test—the oral glucose tolerance test (OGTT), in which a 75 g or 100 g oral glucose load is administered in a fasting state, and plasma glucose levels are evaluated after 1, 2, or 3 hours. A diagnosis of GDM is made in pregnant women when one or more glucose values fall at or above the specified glucose thresholds. Alternatively, a one-step method in which all patients or high-risk patients forego the screening test and proceed directly to the OGTT has been recommended.15

The absence of a universally accepted gold standard for the diagnosis of GDM has resulted in a variety of recommended diagnostic glucose thresholds that have been endorsed by different stakeholders (Table A). These criteria reflect changes that have occurred in laboratory glucose measurements over the years and in new evidence that suggests the ability of different glucose thresholds to predict poor pregnancy outcomes. The different diagnostic criteria and thresholds result in different estimates of the prevalence of GDM.

Table A Diagnostic criteria and plasma glucose thresholds for gestational diabetes mellitus

Organization | Year | Testing Schedule | Abnormal Value(s) | Threshold (Equal to or Greater Than)
Organization | Year | Testing Schedule | Abnormal Value(s) | 0 (h) | 1 (h) | 2 (h) | 3 (h)
ADA | 1999^26^ | 50 g OGCT | 1 | — | 140 mg/dL 7.8 mmol/L | — | —
ADA | 1999^26^ | 100 g OGTT | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
ADA Low risk^†^ excluded | 2000-2010^10,27-36^ | 50 g OGCT | 1 | — | 130 mg/dL 7.2 mmol/L or 140 mg/dL 7.8 mmol/L | — | —
ADA Low risk^†^ excluded | 2000-2010^10,27-36^ | 100 g or 75 g OGTT after overnight fast ≥8hr | 2 or more | 95 mg/dL 5.3 mmol/L | 180 mg/dL 10.0 mmol/L | 155 mg/dL 8.6 mmol/L | 140 mg/dL 7.8 mmol/L (3 hr value only for 100 g test)
IADPSG ADA | 2011^37^ | 75 g OGTT | 1 or more | 92 mg/dL 5.1 mmol/L | 180 mg/dL 10.0 mmol/L | 153 mg/dL 8.5 mmol/L | —
1. CC; 2. 4^th^ IWC (same); 3. 5^th^ IWC (same as 4^th^ but 75 g accepted with same glucose thresholds) | 1. 1982^5^; 2. 1998^38^; 3. 2007^39^ | 50 g OGCT | 1 | — | 130 mg/dL 7.2 mmol/L | — | —
1. CC; 2. 4^th^ IWC (same); 3. 5^th^ IWC (same as 4^th^ but 75 g accepted with same glucose thresholds) | 1. 1982^5^; 2. 1998^38^; 3. 2007^39^ | 100 g OGTT | 2 or more | 95 mg/dL 5.3 mmol/L | 180 mg/dL 10.0 mmol/L | 155 mg/dL 8.6 mmol/L | 140 mg/dL 7.8 mmol/L
NDDG | 1979^40^ | 50 g OGCT | — | — | — | — | —
NDDG | 1979^40^ | 100 g OGTT | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
WHO | 1999 WHO consultation41 | 75 g OGTT | 1 | 6.1 mmol/L for IGT of pregnancy; 7.0 mmol/L for Dx of DM | — | 140 mg/dL 7.8 mmol/L for IGT of pregnancy; 200 mg/dL 11.1 mmol/L for Dx of DM | —
WHO | 1985 WHO study group report42 | 75 g OGTT | 1 | 7.8 mmol/L 140 mg/dL for IGT of pregnancy | — | 7.8 mmol/L (140 mg/dL); for IGT of pregnancy; 200 (11.1 mmol/L) for Dx of DM | —
CDA | 2003, 2008^43,44^ | 50 g OGCT | 1 | — | 140 mg/dL 7.8 mmol/L or 186 mg/dL, 10.3 mmol/L Dx GDM | — | —
CDA | 2003, 2008^43,44^ | 75 g | 2 or more | 95 mg/dL 5.3 mmol/L | 191 mg/dL 10.6 mmol/L | 160 mg/dL 8.9 mmol/L | —
ACOG – risk factor 4^th^ IWC | 2001^14,45^ | 50 g | 1 | — | 130 mg/dL 7.2 mmol/L or 140 mg/dL 7.8 mmol/L | — | —
ACOG – risk factor 4^th^ IWC | 2001^14,45^ | 100 g CC | 2 or more | 95 mg/dL 5.3 mmol/L | 180 mg/dL 10.0 mmol/L | 155 mg/dL 8.5 mmol/L | 140 mg/dL 7.8 mmol/L
ACOG – risk factor 4^th^ IWC | 2001^14,45^ | 100 g NDDG | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
3^rd^ IWC | 1991^46^ | 100 g OGTT | 2 or more | 105 mg/dL 5.8 mmol/L | 190 mg/dL 10.5 mmol/L | 165 mg/dL 9.1 mmol/L | 145 mg/dL 8.0 mmol/L
ADIPS | 1998^47^ | 50 g or 75 g nonfasting | 1 | — | 140 mg/dL 7.8 mmol/L (50 g) or 144 mg/dL 8.0 mmol/L (75 g) | — | —
ADIPS | 1998^47^ | 75 g fasting | 1 | 99 mg/dL 5.5 mmol/L | — | 144 mg/dL 8.0 mmol/L or 162 mg/dL 9.0 mmol/L^*^ | —
EASD | 1996^48^ | 75 g | 1 | 108 mg/dL 6.0 mmol/L | — | 162 mg/dL 9.0 mmol/L | —
USPSTF (Grade 1 recommendation) | 2008^‡^ | Risk assessment 50 g OGCT | 1 | — | 130 mg/dL 7.2 mmol/L or 140 mg/dL 7.8 mmol/L | — | —
USPSTF (Grade 1 recommendation) | 2008^‡^ | 100 g OGTT | 2 or more | NR | NR | NR | NR

ACOG = American College of Obstetricians and Gynecologists; ADA = American Diabetes Association; ADIPS = Australasian Diabetes in Pregnancy Society; CC = Carpenter, Coustan; CDA = Canadian Diabetes Association; DM = diabetes mellitus; Dx = diagnosis; EASD = European Association for the Study of Diabetes; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IGT = impaired glucose tolerance; IWC = International Workshop Conference; NDDG = National Diabetes Data Group; NR = not reported; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; USPSTF = U.S. Preventive Services Task Force; WHO = World Health Organization

† Low risk defined as age <25 yr, normal body weight, no first degree relative with DM, no history of abnormal glucose, no history of poor obstetrical outcomes, not of high risk ethnicity for DM.

* in New Zealand.

‡ Screening for GDM: USPSTF recommendation statement Ann Intern Med 2008;148(10):759-65.

In 2004, a cross-sectional study reported that universal screening was the most common practice in the United States, with 96 percent of obstetricians routinely screening for GDM.16 In contrast, the guidelines of ACOG and the ADA at that time stated that women at low risk for GDM were unlikely to benefit from screening.14,17 Since only 10 percent of pregnant women were categorized as low risk, some argued that selective screening contributed to confusion, with little benefit and potential for harm.18 Of particular concern was the association between risk factor-based screening and high rates of false negative results.19 Others have endorsed alternative risk scoring systems for screening.20

The IADPSG, an international consensus group with representation from multiple obstetrical and diabetes organizations, recently spearheaded a reexamination of the definition of GDM in an attempt to bring uniformity to GDM diagnoses.21 The IADPSG recommended that a one-step 75 g OGTT be given to all pregnant women who do not have a diagnosis of overt diabetes. They also recommended that a single glucose value, rather than at least two abnormal values at or above diagnostic glucose thresholds on the OGTT be accepted as sufficient for a diagnosis of GDM. The diagnostic glucose thresholds recommended by the IADPSG were the maternal glucose values from the HAPO study3 that identified a 1.75-fold increase (adjusted odds ratio relative to the mean cohort glucose values) in large for gestational age, elevated C-peptide, high neonatal body fat, or in a combination of these factors. Since overt diabetes is often asymptomatic, may not have been screened for before conception, has a prevalence that is increasing dramatically in reproductive-age women, and carries a higher risk for poor pregnancy outcomes,22 the IADPSG also recommended that all women, or at least women from high-risk groups for type 2 diabetes mellitus, be screened for overt diabetes at their first prenatal visit and excluded from the diagnosis of GDM using one of the following criteria: fasting plasma glucose ≥126 mg/dL (7.0 mmol/L), glycated hemoglobin (HbA1c) ≥6.5 percent (Diabetes Chronic Complications Trial/United Kingdom Prospective Diabetes Study standardized), or a random plasma glucose ≥200 mg/dL (11.1 mmol/L) confirmed by one of the first two measures.

### Treatment Strategies

Initial treatment for GDM involves diet modification, glucose monitoring, and moderate exercise. When dietary management does not achieve desired glucose control, insulin or oral antidiabetic medications may be used.23 Increased prenatal surveillance may also occur as well as changes in delivery management depending on fetal size and the effectiveness of measures to control glucose.

### Scope of the Review

Based on systematic reviews published in 2003 and 2008, the USPSTF concluded that there was insufficient evidence upon which to make a recommendation regarding routine screening of all pregnant women for GDM.13,24 Several key studies have been published since the 2008 USPSTF evidence report.3,8,25 The National Institutes of Health's Office of Medical Applications of Research (OMAR) commissioned this report (specifically Key Questions 3 to 5, see section below), which the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) Program conducted. OMAR will use the review to inform members of consensus meetings and inform guideline development. The USPSTF joined this effort and will use the review to update its recommendation on screening for GDM (Key Questions 1 and 2).

The primary aims of this review were to (1) identify the test properties of screening and diagnostic tests for GDM, (2) evaluate the potential benefits and harms of screening at ≥24 weeks and <24 weeks' gestation, (3) assess the effects of different screening and diagnostic thresholds on outcomes for mothers and their offspring, and (4) determine the effects of treatment in modifying outcomes for women diagnosed with GDM. The benefits and harms of treatments were considered in this review to determine the downstream effects of screening on health outcomes. The intent of this review was also to assess whether evidence gaps in the previous USPSTF reviews have been filled. These gaps included lack of sufficient evidence to determine whether maternal or fetal complications are reduced by screening; lack of screening studies with adequate power to evaluate health outcomes such as mortality, neonatal intensive care unit (NICU) admissions, hyperbilirubinemia; limited evidence on the accuracy of screening strategies; and insufficient evidence on the benefits of treating GDM in improving health outcomes.

## Key Questions

OMAR and USPSTF developed the Key Questions for this evidence synthesis to inform members of consensus meetings and inform guideline development; OMAR specifically developed Key Questions 3 to 5. Investigators from the University of Alberta EPC worked in consultation with representatives from the AHRQ EPC Program, OMAR and the USPSTF, and a panel of Technical Experts to operationalize the Key Questions. The Technical Expert Panel provided content and methodological expertise throughout the development of this evidence synthesis. Participants in this panel are identified in the front matter of this report. The Key Questions are as follows:

Key Question 1: What are the sensitivities, specificities, reliabilities, and yields of current screening tests for GDM? (a) After 24 weeks' gestation? (b) During the first trimester and up to 24 weeks' gestation?

Key Question 2: What is the direct evidence on the benefits and harms of screening women (before and after 24 weeks' gestation) for GDM to reduce maternal, fetal, and infant morbidity and mortality?

Key Question 3: In the absence of treatment, how do health outcomes of mothers who meet various criteria for GDM and their offspring compare to those who do not meet the various criteria?

Key Question 4: Does treatment modify the health outcomes of mothers who meet various criteria for GDM and their offspring?

Key Question 5: What are the harms of treating GDM and do they vary by diagnostic approach?

## Methods

### Literature Search

We systematically searched the following bibliographic databases for studies published from 1995 to May 2012: MEDLINE^®^ Ovid, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations, Cochrane Central Register of Controlled Trials (contains the Cochrane Pregnancy and Childbirth Group, which hand searches journals pertinent to its content area and adds relevant trials to the registry), Cochrane Database of Systematic Reviews (CDSR), Database of Abstracts of Reviews of Effects (DARE), Global Health, Embase, Pascal CINAHL Plus with Full Text (EBSCO host), BIOSIS Previews^®^ (Web of KnowledgeSM), Science Citation Index Expanded^®^ and Conference Proceedings Citation Index- Science (both via Web of ScienceSM), PubMed^®^, LILACS (Latin American and Caribbean Health Science Literature), National Library of Medicine (NLM) Gateway, and OCLC ProceedingsFirst and PapersFirst. We searched trial registries, including the WHO International Clinical Trials Registry Platform (ICTRP), ClinicalTrials.gov, and Current Controlled Trials. We limited the search to trials and cohort studies published in English.

We searched the Web sites of relevant professional associations and research groups, including the ADA, IADPSG, International Symposium of Diabetes in Pregnancy, and Diabetes in Pregnancy Society for conference abstracts and proceedings from the past 3 years. We reviewed the reference lists of relevant reviews (including the 2008 USPSTF review) and studies that were included in this report.

### Study Selection

Two reviewers independently screened the titles and abstracts using broad inclusion criteria. We retrieved the full text of articles classified as “include” or “unclear.” Two reviewers independently assessed each full-text article using a priori inclusion criteria and a standardized form. We resolved disagreements by consensus or third-party adjudication.

We included published randomized controlled trials (RCTs), nonrandomized controlled trials (NRCTs), and prospective and retrospective cohort studies. For Key Question 1, we excluded retrospective cohort studies. We included studies of pregnant women ≥24 weeks' gestation or <24 weeks' gestation, with no known history of preexisting diabetes. Comparisons of interest varied by Key Question and were as follows: Key Question 1 – any GDM screening or diagnostic test compared with any GDM reference standard or other screening or diagnostic test; Key Question 2 – any GDM screening versus no GDM screening; Key Question 3 – women who met various thresholds for GDM versus those who did not meet various criteria for GDM, where women in both groups did not receive treatment; Key Questions 4 and 5 – any treatment for GDM, including but not limited to dietary advice, blood glucose monitoring, insulin therapy (all preparations), and oral hypoglycemic agents versus no treatment. Studies meeting these eligibility criteria were included if they reported data for at least one outcome specified in the Key Questions. We included studies regardless of setting and duration of followup.

### Quality Assessment

Two reviewers independently assessed the methodological quality of studies and resolved discrepancies by discussion and consensus. For Key Question 1, we used the QUADAS-2 checklist49 to assessthe quality of diagnostic accuracy studies. We assessed the internal validity of RCTs and NRCTs using the Cochrane Collaboration Risk of Bias tool. For cohort studies, we used the Newcastle-Ottawa Scale. For Key Questions 2 to 5, we summarized the quality of individual studies as “good,” “fair,” or “poor” based on criteria specific to each tool.

### Data Extraction and Synthesis

One reviewer extracted data using a standardized form, and a second reviewer checked the data for accuracy and completeness. We extracted information on study characteristics, inclusion and exclusion criteria, participant characteristics, details of the interventions or diagnostic/screening tests (as appropriate), and outcomes. Reviewers resolved discrepancies by consensus or in consultation with a third party.

For each Key Question, we presented evidence tables detailing each study and provided a qualitative description of results. For Key Question 1, we constructed 2×2 tables and calculated sensitivity, specificity, positive and negative predictive values, reliability (i.e., accuracy), and yield (i.e., prevalence) of the screening or diagnostic tests. If studies were clinically homogenous, we pooled sensitivities and specificities using a hierarchical summary receiver-operator curve and bivariate analysis of sensitivity and specificity.50 For the other Key Questions, we combined studies in a meta-analysis if the study design, population, comparisons, and outcomes were sufficiently similar. Results were combined using random effects models. We quantified statistical heterogeneity using the I-squared (I^2^) statistic. When I^2^ was greater than 75 percent, we did not pool results, and we investigated potential sources of heterogeneity.

### Strength of the Body of Evidence

Two independent reviewers graded the strength of the evidence for Key Questions 3 and 4 using the EPC GRADE (Grading of Recommendations Assessment, Development and Evaluation) approach and resolved discrepancies by discussion and consensus. We graded the evidence for the following key outcomes: birth injury, preeclampsia, neonatal hypoglycemia, maternal weight gain, and long-term metabolic outcomes of the child and mother. We made a post hoc decision to grade shoulder dystocia and macrosomia. These were not included in the protocol as outcomes that would be graded but were felt by the clinical investigators to be important to grade during the course of preparing the review. For each outcome, we assessed four major domains: risk of bias (rated as low, moderate, or high), consistency (rated as consistent, inconsistent, or unknown), directness (rated as direct or indirect), and precision (rated as precise or imprecise). The overall strength of evidence was graded as high, moderate, low, or insufficient.

### Applicability

We assessed the applicability of the body of evidence following the PICOTS (population, intervention, comparator, outcomes, timing of outcome measurement, and setting) format used to assess study characteristics. Factors that may potentially limit applicability were discussed.

### Peer Review and Public Commentary

Peer reviewers were invited to provide written comments on the draft report based on their clinical, content, or methodologic expertise. Peer reviewer comments on the draft report were addressed by the EPC in preparation of the final draft of the report. Peer reviewers do not participate in writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments are documented and will be published 3 months after the publication of the Evidence Report.

Potential reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited peer reviewers may not have any financial conflict of interest greater than $10,000. Peer reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through AHRQ's public comment mechanism.

## Results

### Description of Included Studies

The search identified 14,398 citations, and 97 studies were included: 6 RCTs, 63 prospective cohort studies, and 28 retrospective cohort studies. The studies were published between 1995 and 2012 (median 2004). Studies were conducted in the United States (24 percent), Europe (23 percent), Asia (22 percent), the Middle East (20 percent), Australia (4 percent), Central and South America (3 percent), and Canada (4 percent). The number of women enrolled in each study ranged from 32 to 23,316 (median 750). The mean age of study participants was 30 years.

Forty-eight studies (50 percent) analyzed women tested for GDM between 24 and 28 weeks, with an OGCT taking place first and the OGTT following within 7 days. Thirty-one studies (32 percent) did not specify when screening or diagnostic procedures took place. Eighteen studies (18 percent) screened or tested within unique time ranges. Of these, one study screened participants with an OGCT at 21–23 weeks followed by a diagnostic OGTT at 24–28 weeks; another screened a group of participants after 37 weeks; one study screened before 24 weeks; another screened women at risk between 14 and 16 weeks, with normal women screened at the usual 24–28 weeks; and one study screened between 16 and 20 weeks or between 17 and 21 weeks followed by a diagnostic OGTT at 26–32 weeks. Remaining studies generally provided broader screening times ranging from 21 to 32 weeks' gestation. Studies employing WHO criteria generally screened further into gestation as only an OGTT was performed: one study screened at 28–32 weeks, and another study screened women at high risk at 18–20 weeks and others at 28–30 weeks.

### Methodological Quality of Included Studies

The methodological quality was assessed using different tools depending on the Key Question and study design: QUADAS-2 was used for Key Question 1; for Key Questions 2 to 5, the Cochrane Risk of Bias tool was used for RCTs and the Newcastle Ottawa Scale was used for cohort studies. The methodological quality of studies is summarized for each Key Question below.

### Results of Included Studies

The results are presented by Key Question in the sections that follow. A summary of the results for all Key Questions is provided in Table D.

Table D Summary of evidence for all Key Questions

Key Question | Number and Quality of Studies | Limitations/Consistency | Applicability | Summary of Findings
KQ1. What are the sensitivities, specificities, reliabilities, and yields of current screening tests for GDM? (a) After 24 weeks' gestation? (b) During the first trimester and up to 24 weeks' gestation? | (a) After 24 wk gestation 51 prospective studies Fair to good quality | Limitations: Lack of an agreed upon gold standard for diagnosis of GDM creates challenges for assessing the accuracy of tests and comparing across studies. GDM was confirmed using criteria developed by CC, ADA, NDDG, and WHO There were sparse data comparing overall approaches for diagnosis and screening, e.g., one-step vs. two-step, selective vs. universal. Consistency: Across studies numerous tests and thresholds were examined. Screening tests included the 50 g OGCT, FPG, risk factor-based screening, and other less common tests such as HbA1c, serum fructosamine. | Prevalence of GDM varied across studies and diagnostic criteria used. Results need to be interpreted in the context of prevalence. Comparisons involving WHO criteria are less applicable to the North American setting because these criteria are not used in North America. | - Prevalence varied across studies and diagnostic criteria: ADA 2000-2010 (75 g) 2.0 to 19% (range), CC 3.6 to 38%, NDDG 1.4 to 50%, WHO 2 to 24.5%.; - 9 studies examined a 50 g OGCT with a cutoff value of ≥140 mg/dL; GDM was confirmed using CC criteria. Results: sensitivity 85%, specificity 86%, prevalence 3.8 to 31.9%, PPV 18 to 27% (prevalence <10), PPV 32 to 83% (prevalence ≥10), NPV median 98%.; - 6 studies examined a 50 g OGCT (≥130 mg/dL); GDM was confirmed using CC criteria. Results: sensitivity 99%, specificity 77%, prevalence 4.3 to 29.5%, PPV 11 to 31% (prevalence <10), PPV 31 to 62% (prevalence ≥10), NPV median 100%.; - 1 study examined a 50 g OGCT (≥200 mg/dL); GDM was confirmed using CC criteria. Sensitivity, specificity, PPV, and NPV were all 100%. Prevalence was 6.4%.; - 7 studies examined a 50 g OGCT (≥140 mg/dL); GDM was confirmed using NDDG criteria. Results: sensitivity 85%, specificity 83%, prevalence 1.4 to 45.8%, PPV 12 to 39% (prevalence <10), PPV 57% (prevalence ≥10), NPV median 99%.; - 3 studies examined a 50 g OGCT (≥130 mg/dL); GDM was confirmed using NDDG criteria. Results: sensitivity 67 to 90% (range), specificity 47 to 84%; prevalence 16.7 to 35.3%, PPV 20 to 75%, NPV 86 to 95%.; - 3 studies examined a 50 g OGCT (different thresholds); GDM was confirmed using ADA 2000-2010 (75 g) criteria. Prevalence was 1.6 to 4.1% (range). Results: sensitivity 86 to 97% (range), specificity 79 to 87%; PPV 7 to 20%, NPV 99 to 100%.
| (a) After 24 wk gestation 51 prospective studies Fair to good quality | (a) After 24 wk gestation 51 prospective studies Fair to good quality | | - 3 studies examined a 50 g OGCT (≥140 mg/dL); GDM was confirmed using WHO criteria. Results: sensitivity 43 to 85%, specificity 73 to 94%, prevalence 3.7 to 15.7%, PPV 18 to 20% (prevalence <10), PPV 58% (prevalence ≥10), NPV median 99%.; - 7 studies examined FPG at different thresholds; GDM was confirmed using CC criteria. Results: at ≥85 mg/dL sensitivity 87%, specificity 52%; at ≥90 mg/dL sensitivity 77%, specificity 76%; at ≥92 mg/dL sensitivity 76%, specificity 92%; at ≥95 mg/dL sensitivity 54%, specificity 93%. At ≥85 mg/dL prevalence 1.4 to 34.53 (range). PPV 10% (prevalence <10) and 23 to 59% (prevalence ≥10). Median NPV 93%.; - 8 studies examined risk factor-based screening but were not pooled. Studies used different criteria to confirm GDM. Results: sensitivity 48 to 95% (range), specificity 22 to 94%, prevalence 1.7 to 16.9%, PPV 5 to 19% (prevalence <10), PPV 20% (prevalence ≥10), NPV median 99%.; - 1 study compared IADPSG vs. ADIPS 2 step (reference) to diagnose GDM. Results: sensitivity 82%, specificity 94%, prevalence 13.0%, PPV 61%, NPV 98%.; - 4 studies compared 75 g and 100 g load tests to diagnose GDM. Prevalence ranged from 1.4 to 50%. Results were not pooled: sensitivity 18 to 100%, specificity 86 to 100%, PPV 12 to 100%, NPV 62 to 100%.
| (b) During the first trimester and up to 24 wk gestation 3 prospective cohort studies | Limitations: Only 3 studies of women before 24 wks gestation; therefore, no conclusions can be made for test characteristics in early pregnancy. Consistency: Not applicable (not enough studies addressing the same question to judge consistency). | Evidence too limited to judge applicability. | - 1 study examined the 50 g OGCT at 10 wks and confirmed GDM using JSOG criteria (75 g). Results: sensitivity 88%, specificity 79%, prevalence 1.6%, PPV 7%, NPV 100%.; - 1 study examined 50 g OGCT at 20 wks and confirmed GDM using ADA (2000-2010) 100 g criteria. Results: sensitivity 56%, specificity 94%, prevalence 3.6%, PPV 24%, NPV 98%.; - 1 study compared 1^st^ and 2^nd^ trimester results using 3 screening tests (OGCT at ≥130 mg/dL, FPG, HbA1c); GDM confirmed using JSOG criteria. Results (OGCT) 1^st^ trimester: prevalence 1.9%, sensitivity 93%, specificity 77%, PPV 7.1, NPV 99%; 2^nd^ trimester: prevalence 2.9%, sensitivity 100%, specificity 85%, PPV 17%, NPV 100%.
KQ2: What is the direct evidence on the benefits and harms of screening women (before and after 24 weeks' gestation) for GDM to reduce maternal, fetal, and infant morbidity and mortality? | 2 retrospective cohort studies Fair and good quality | Limitations: No RCTs available to answer this question. Consistency: Not applicable (not enough studies addressing the same question to judge consistency). | The comparison for this question was women who had and had not undergone screening. Since screening is now commonplace, it may be unlikely to identify studies or cohorts where this comparison is feasible. | 1 study (n=1,000) showed more cesarean deliveries in the screened group. A second study (n=93) found the incidence of macrosomia (≥4.3 kg) was the same in screened and unscreened groups (7% each group). Based on the small number of studies and sample sizes, the effect of screening women for GDM on health outcomes is inconclusive.
KQ3: In the absence of treatment, how do health outcomes of mothers who meet various criteria for GDM and their offspring compare to those who do not meet the various criteria? | 38 prospective or retrospective cohort studies; 2 studies were long-term followup from RCTs; however, only data from the untreated patients were included. Fair to good quality | Limitations: Strength of evidence was low to insufficient for all graded outcomes due to risk of bias (all observational studies), inconsistency, and/or imprecision. For many comparisons, the numbers of studies, participants, and/or events was low; therefore, findings of no statistically significant differences between groups do not imply equivalence or rule out potential differences. Consistency: A wide variety of diagnostic criteria and thresholds were compared across studies. There were often few studies with similar comparison groups. Differences in defining and assessing outcomes may have contributed to heterogeneity in results across studies (e.g., biochemical vs. clinical assessment of neonatal hypoglycemia). | All studies or groups included for analysis involved women who had not received treatment for GDM. These women may differ from the general population in other ways that are related to the reasons why they did not seek or receive early prenatal care (e.g., socioeconomic status). | Maternal outcomes:; - A methodologically strong study showed a continuous positive relationship between increasing glucose levels and the incidence of primary cesarean section. This study also found significantly fewer cases of preeclampsia and cesarean section for women with no GDM vs. IADPSG.; - For preeclampsia, significant differences were found for CC vs. patients with no GDM (3 studies), with fewer cases among the patients with no GDM, and for CC vs. false-positive groups (2 studies), with fewer cases among the false positives. The strength of evidence was low. No differences were found for NDDG false positive (2 studies), NDDG 1 abnormal OGTT vs. no GDM (1 study), or IGT WHO vs. no GDM (3 studies); the strength of evidence was insufficient.; - For maternal weight gain, significant differences were found for 3 of 12 comparisons: IADPSG IGT vs. no GDM (favored IGT), IADPSG IFG vs. no GDM (favored IFG), IADPSG IGT-2 vs. no GDM (favored IGT-2). All comparisons were based on single studies (strength of evidence insufficient).; Fetal/neonatal/child outcomes:; - 2 methodologically strong studies showed a continuous positive relationship between increasing glucose levels and the incidence of macrosomia. 1 of these studies also showed significantly fewer cases of shoulder dystocia and/or birth injury, clinical neonatal hypoglycemia, and hyperbilirubinemia for women with no GDM vs. IADPSG.; - For macrosomia >4,000 g, 6 of 11 comparisons showed a significant difference: patient groups with no GDM had fewer cases compared with CC GDM (10 studies), CC 1 abnormal OGTT (7 studies), NDDG GDM (unrecognized) (1 study), NDDG false positives (4 studies), and WHO IGT (1 study). Fewer cases were found for women with false-positive results compared with CC GDM (5 studies). Data for macrosomia >4,500 g were available for 4 comparisons and showed significant differences in 2 cases: patient groups with no GDM had fewer cases compared with CC GDM (3 studies) and unrecognized NDDG GDM (1 study). The strength of evidence for macrosomia was low to insufficient.; - For shoulder dystocia, significant differences were found for 7 of 17 comparisons; all comparisons but 1 were based on single studies (insufficient strength of evidence). Patient groups with no GDM showed lower incidence of shoulder dystocia when compared with CC GDM (5 studies, low strength of evidence), NDDG GDM (unrecognized), NDDG false positive, WHO IGT, IADPSG IFG, and IADPSG IGT IFG. The other significant difference showed lower incidence among the false-positive group compared with CC 1 abnormal OGTT.; - For fetal birth trauma/injury, single studies compared CC GDM and WHO IGT with no GDM and showed no differences. Two studies showed fewer cases for no GDM compared with NDDG GDM. Strength of evidence was insufficient for all comparisons.; - No differences were found for neonatal hypoglycemia for any comparison, including CC GDM vs. no GDM (3 studies), CC GDM vs. 1 abnormal OGTT (1 study), CC 1 abnormal OGTT vs. no GDM (4 studies), NDDG GDM vs. no GDM (1 study), NDDG false positive vs. no GDM (1 study), and WHO IGT vs. no GDM (3 studies). Strength of evidence was insufficient for all comparisons.
KQ4: Does treatment modify the health outcomes of mothers who meet various criteria for GDM and offspring? | 5 RCTs and 6 retrospective cohort studies. Poor to good quality | Limitations: For some outcomes, particularly the long-term outcomes, the strength of evidence was insufficient or low. Moreover, for some outcomes events were rare, and the studies may not have had the power to detect clinically important differences between groups; therefore, findings of no significant difference should not be interpreted as equivalence between groups. Consistency: Some inconsistency occurred at 2 levels. First, there were inconsistencies for some outcomes between RCTs and observational studies, which may be attributable to confounding and methods of selecting study groups (e.g., historical control groups). Second, in some instances there were inconsistencies across studies within designs, that were often attributable to the manner in which outcomes were defined or assessed (e.g., clinical vs. biochemical assessment of neonatal hypoglycemia). | For the most part, study populations included women whose glucose intolerance was less marked, as those whose glucose intolerance was more pronounced would not be entered into a trial in which they may be assigned to a group receiving no treatment. The majority of studies were conducted in North America or Australia, with 2 from Italy. Most of the North American studies were inclusive of mixed racial populations and are likely applicable to the general U.S. population. Even though the Australian RCT population had more white women with a lower BMI than the U.S. RCTs; this should not affect applicability of most of their findings for the U.S. women because these subject characteristics would be factors associated with lower risk of poor outcomes. | Maternal outcomes:; - Moderate evidence from 3 RCTs showed a significant difference for preeclampsia, with fewer cases in the treated group.; - There was inconsistency across studies in terms of maternal weight gain (4 RCTs and 2 cohort studies); the strength of evidence was insufficient due to inconsistency and imprecision in effect estimates.; Offspring outcomes:; - There was insufficient evidence to make a conclusion for birth injury. There was inconsistency across studies, with the 2 RCTs showing no difference and the 1 cohort study showing a difference in favor of the treated group. The low number of events and participants across all studies resulted in imprecise estimates.; - Moderate evidence showed significantly lower incidence of shoulder dystocia in the treated groups, and this finding was consistent for the 3 RCTs and 4 cohort studies.; - There was low evidence of no difference between groups for neonatal hypoglycemia based on 4 RCTs and 2 cohort studies.; - For outcomes related to birthweight (including macrosomia >4,000 g, macrosomia >4,500 g, actual birthweight, and large for gestational age), differences were often observed favoring the treated groups. Strength of evidence was moderate for macrosomia >4,000 g.; - 1 RCT followed patients for 7 to 11 years and found no differences for impaired glucose tolerance or type 2 DM, although the strength of evidence was considered insufficient.; - No differences were observed in single studies that assessed BMI >95 (7-11 yr followup) and BMI >85 percentile (5-7 yr followup). Overall, pooled results showed no difference in BMI, and the strength of evidence was considered low.
KQ5: What are the harms of treating GDM and do they vary by diagnostic approach? | 4 RCTs and 1 retrospective cohort study. Fair to good quality | Limitations: No study evaluated costs and resource allocation. Limited evidence on harms. Limited evidence for number of prenatal visits and NICU admissions. Findings of no significant differences may be attributable to low power and should not be interpreted as equivalence. Consistency: Not applicable (not enough studies addressing the same question to judge). | As above for KQ4. In addition, differences in billing structures between the United States and Australia may have accounted for the discrepant findings with respect to NICU admissions between these studies and as a result limit the applicability of this finding in the United States. | - 1 RCT assessed depression and anxiety at 6 weeks after study entry and 3 months postpartum.; - There was no significant difference between groups in anxiety at either time point, although there were significantly lower rates of depression in the treatment group at 3 months postpartum.; - 4 RCTs reported small for gestational age and found no significant difference.; - 3 RCTs and 1 cohort study provided data on admission to NICU and showed no significant differences overall. One trial was an outlier because it showed a significant difference favoring the no treatment group. This difference may be attributable to site-specific policies and procedures.; - 2 RCTs reported on the number of prenatal visits and generally found more visits among the treatment groups.; - 2 RCTs reporting on induction of labor showed different results, with 1 showing a significant difference with more cases in the treatment group and the other showing no difference.; - Based on studies included in KQ4, no differences between groups were found for cesarean section (5 RCTs, 6 cohorts) or unplanned cesarean section (1 RCT, 1 cohort).

ADA = American Diabetes Association; ADIPS = Australasian Diabetes in Pregnancy Society; BMI = body mass index; CC = Carpenter and Coustan; DM = type 2 diabetes mellitus; FPG = fasting plasma glucose; GDM = gestational diabetes mellitus; HbA1c = glycated hemoglobin; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; IGT-2 = double impaired glucose tolerance; JSOG = Japan Society of Obstetrics and Gynecology; NDDG = National Diabetes Data Group; NPV = negative predictive value; NICU = neonatal intensive care unit; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; PPV = positive predictive value; RCT = randomized controlled trial; wk(s) = week(s); WHO = World Health Organization

#### Key Question 1

Fifty-one studies provided data for Key Question 1, which examined the diagnostic test characteristics and prevalence of current screening and diagnostic tests for GDM. Studies were conducted in a range of geographic regions: 11 in North America, 10 in Europe, 12 in Asia, 15 in the Middle East, 2 in South America, and 1 in Australia. Studies reported on findings for a number of screening tests, including the 50 g OGCT, fasting plasma glucose (FPG), and risk factor-based screening, as well as other, less common tests such as HbA1c, serum fructosamine, and adiponectin. GDM was confirmed using criteria developed by different groups, including CC, ADA, National Diabetes Data Group (NDDG), and WHO. The lack of a gold standard to confirm a diagnosis of GDM limits the ability to compare the results of studies that have used different diagnostic criteria. Different criteria result in different rates of prevalence, regardless of similarities across study settings and patient characteristics. A summary of the results is provided in Table D.

Methodological quality of the studies was assessed using the QUADAS-2 tool. The domain of patient selection was rated as low risk for 53 percent and unclear risk for 22 percent of the studies. Overall, 55 percent were assessed as having high concerns about applicability for this domain. This was primarily because these studies were conducted in developing countries and used the WHO criteria to diagnose GDM. The domain of the index test was generally rated as low risk of bias (53 percent). Concern about applicability was assessed as low (82 percent). The domain of the reference standard (i.e., the criteria used to confirm a diagnosis of GDM) was rated as high or unclear risk (80 percent). For most studies, the result of the screening test was used to determine whether patients underwent further testing for GDM (lack of blinding) or it was unclear. Concern about applicability for this domain was assessed as low (84 percent). The domain of flow and timing was assessed as low risk of bias in 39 percent of studies. However, 35 percent were assessed as unclear risk of bias because not all patients received a confirmatory reference standard if the screening test was below a certain threshold, so there is a risk of diagnostic review bias.

Nine studies provided data to estimate sensitivity and specificity of a 50 g OGCT (cutoff ≥140 mg/dL); GDM was confirmed using a 100 g, 3-hour OGTT using CC criteria. Sensitivity and specificity were 85 percent (95% CI, 76 to 90) and 86 percent (95% CI, 80 to 90), respectively. Prevalence ranged from 3.8 to 31.9 percent. When prevalence was less than 10 percent, PPV ranged from 18 to 27 percent; when prevalence was 10 percent or more, PPV ranged from 32 to 83 percent. The median NPV for all studies was 98 percent.

Six studies reported results for a 50 g OGCT (cutoff ≥130 mg/dL); GDM was confirmed using the CC criteria. Sensitivity was 99 percent (95% CI, 95 to 100) and specificity was 77 percent (95% CI, 68 to 83). Prevalence ranged from 4.3 to 29.8 percent. When prevalence was less than 10 percent, PPV ranged from 11 to 27 percent; when prevalence was 10 percent or more, PPV ranged from 31 to 62 percent. The median NPV for all studies was 100 percent.

One study assessed a 50 g OGCT with a cutoff value of ≥200 mg/dL; GDM was confirmed using the CC criteria. Prevalence was 6.4 percent. Sensitivity, specificity, PPV and NPV were all 100 percent.

The evidence showed that the 50 g OGCT with the 130 mg/dL cutpoint had higher sensitivity when compared with the 140 mg/dL cutpoint; however, specificity was lower. Both thresholds have high NPVs, but variable PPVs across a range of GDM prevalence. The Toronto Trihospital study found evidence to support the use of the lower screening cutpoint for higher risk patients, and the higher screening cutpoint for lower risk patients.12

Seven studies assessed a 50 g OGCT (≥140 mg/dL); GDM was confirmed using the NDDG criteria. Sensitivity was 85 percent (95% CI, 73 to 92) and specificity was 83 percent (95% CI, 78 to 87). Prevalence ranged from 1.4 to 45.8 percent. When prevalence was less than 10 percent, PPV ranged from 12 to 39 percent; prevalence was more than 10 percent in one study and PPV was 57 percent. The median NPV for all studies was 99 percent. Three studies that assessed a 50 g OGCT (≥130 mg/dL) using NDDG were not pooled. Prevalence ranged from 16.7 to 35.3 percent. PPV ranged from 20 to 75 percent; NPV ranged from 86 to 95 percent.

Three studies assessed a 50 g OGCT (different thresholds); GDM was confirmed using the ADA 2000-2010 75 g, 2 hour criteria. Sensitivity ranged from 86 to 97 percent; specificity ranged from 79 to 87 percent. Prevalence ranged from 1.6 to 4.1 percent. PPV ranged from 7 to 20 percent; NPV ranged from 99 to 100 percent.

Three studies assessed a 50 g OGCT (≥140 mg/dL) with GDM confirmed using the WHO 75 g criteria. Sensitivity was 43 to 85 percent and specificity was 73 to 94 percent. Prevalence ranged from 3.7 to 15.7. In two studies with prevalence less than 10 percent, PPV was 18 and 20 percent; in one study in which prevalence was 10 or more, PPV was 58 percent. The median NPV for all studies was 99 percent.

Seven studies assessed FPG to screen for GDM; GDM was confirmed using CC criteria. Four FPG thresholds were compared— ≥85 mg/dL: sensitivity was 87 percent (95% CI, 81 to 91) and specificity was 52 percent (95% CI, 50 to 55); ≥90 mg/dL: sensitivity was 77 percent (95% CI, 66 to 85) and specificity was 76 percent (95% CI, 75 to77); ≥92 mg/dL: sensitivity was 76 percent (95% CI, 55 to 91) and specificity 92 percent (95% CI, 86 to 96); ≥95 mg/dL: sensitivity was 54 percent (95% CI, 32 to 74) and specificity was 93 percent (95% CI, 90 to 96). While the effect on health outcomes was not part of this Key Question, the Toronto Trihospital and HAPO studies demonstrated the ability of using fasting glucose to predict GDM outcomes.

Limited data support the use of HbA1c as a screening test. One study conducted in the United Arab Emirates using an HbA1c value of 5.5 percent or more lacked specificity (21 percent) despite good sensitivity (82 percent). A study conducted in Turkey showed that an HbA1c cutoff of 7.2 percent or more had 64 percent sensitivity and specificity. HbA1c does not perform as well as the 50 g OGCT as a screening test for GDM. However, when HbA1c is markedly elevated, this supports a possible diagnosis of overt diabetes discovered in pregnancy. Since 2011–2012, the ADA has endorsed the use of an HbA1c of 6.5 percent or more as diagnostic of diabetes in nonpregnant women.36

Although eight studies examined risk factors for screening women, our review did not identify compelling evidence for or against risk factor-based screening. Studies used different diagnostic criteria and could not be pooled. Sensitivity and specificity varied widely across studies.

Only three studies included women who were in their first trimester of pregnancy, and they used different diagnostic criteria. Therefore, no conclusions can be made about the test characteristics of the screening tests for this group of women.

Four studies compared the 75 g and 100 g load tests, but they were conducted in different countries and used different criteria or thresholds. The prevalence of GDM ranged from 1.4 to 50 percent. Sensitivity and specificity varied widely across studies. Limited data are available to draw conclusions about the effectiveness of the different options for diagnostic testing for GDM. However, because both the 75 g and 100 g load tests are positively linked with outcomes3,51 and the 75 g test is less time consuming, the adoption of the 75 g glucose load may be warranted, even if thresholds continue to be debated.3,51

The IADPSG has proposed the elimination of a screening test in favor of proceeding directly to a diagnostic test for GDM. We identified only one study that compared the IADPSG criteria with the Australasian Diabetes in Pregnancy Society (two-step) criteria. The sensitivity was 82 percent (95% CI: 74 to 88) and specificity was 94 percent (95% CI: 93 to 96); the PPV and NPV were 61 percent (95% CI: 53 to 68) and 98 (95% CI: 97 to 99), respectively.

##### Prevalence and Predictive Values

The prevalence of GDM varied across studies and the diagnostic criteria used. Factors contributing to the variability included differences in study setting (i.e., country), screening practices (e.g., universal vs. selective), and population characteristics (e.g., race/ethnicity, age, BMI).

The predictive value of a screening or diagnostic test is determined by the test's sensitivity and specificity and by the prevalence of GDM. Table B presents a series of scenarios that demonstrate the changes in PPV and NPV for three levels of prevalence (7 percent, 15 percent, and 25 percent).6 Separate tables are presented for different screening and diagnostic criteria. The higher the prevalence of GDM, the higher the PPV, or the more likely a positive result is able to predict the presence of GDM. When the prevalence of GDM is low, the PPV is also low, even when the test has high sensitivity and specificity. Generally the NPV (negative result rules out GDM) is very high—98 percent or better at a GDM prevalence of 7 percent.

Table B Relationship between predictive values and prevalence for different screening tests

Screening Test | Prevalence | Positive Predictive Value | Negative Predictive Value
50 g OGCT ≥140 mg/dL by CC/ADA (2000-2010) Sensitivity=85%; Specificity=86% | 7% | 31% | 99%
50 g OGCT ≥140 mg/dL by CC/ADA (2000-2010) Sensitivity=85%; Specificity=86% | 15% | 52% | 97%
50 g OGCT ≥140 mg/dL by CC/ADA (2000-2010) Sensitivity=85%; Specificity=86% | 25% | 67% | 95%
50 g OGCT ≥130 mg/dL by CC/ADA (2000-2010) Sensitivity=99%; Specificity=77% | 7% | 24% | 100%
50 g OGCT ≥130 mg/dL by CC/ADA (2000-2010) Sensitivity=99%; Specificity=77% | 15% | 43% | 100%
50 g OGCT ≥130 mg/dL by CC/ADA (2000-2010) Sensitivity=99%; Specificity=77% | 25% | 59% | 100%
50 g OGCT ≥140 mg/dL by NDDG Sensitivity=85%; Specificity=83% | 7% | 27% | 99%
50 g OGCT ≥140 mg/dL by NDDG Sensitivity=85%; Specificity=83% | 15% | 47% | 97%
50 g OGCT ≥140 mg/dL by NDDG Sensitivity=85%; Specificity=83% | 25% | 63% | 94%
50 g OGCT ≥130 mg/dL by NDDG Sensitivity=88%; Specificity=66% (median) | 7% | 16% | 99%
50 g OGCT ≥130 mg/dL by NDDG Sensitivity=88%; Specificity=66% (median) | 15% | 31% | 97%
50 g OGCT ≥130 mg/dL by NDDG Sensitivity=88%; Specificity=66% (median) | 25% | 46% | 94%
50 g OGCT ≥140 mg/dL by ADA 75 g Sensitivity=88%; Specificity=84% (median) | 7% | 29% | 99%
50 g OGCT ≥140 mg/dL by ADA 75 g Sensitivity=88%; Specificity=84% (median) | 15% | 49% | 98%
50 g OGCT ≥140 mg/dL by ADA 75 g Sensitivity=88%; Specificity=84% (median) | 25% | 65% | 95%
50 g OGCT ≥140 mg/dL by WHO Sensitivity=78%; Specificity=81% (median) | 7% | 24% | 98%
50 g OGCT ≥140 mg/dL by WHO Sensitivity=78%; Specificity=81% (median) | 15% | 42% | 95%
50 g OGCT ≥140 mg/dL by WHO Sensitivity=78%; Specificity=81% (median) | 25% | 58% | 92%
FPG (≥85 mg/dL) by CC/ADA (2000-2010) Sensitivity = 87%; Specificity = 52% | 7% | 12% | 98%
FPG (≥85 mg/dL) by CC/ADA (2000-2010) Sensitivity = 87%; Specificity = 52% | 15% | 24% | 96%
FPG (≥85 mg/dL) by CC/ADA (2000-2010) Sensitivity = 87%; Specificity = 52% | 25% | 38% | 92%
Risk factor screening by various criteria Sensitivity=84%; Specificity=72% (median) | 7% | 21% | 98%
Risk factor screening by various criteria Sensitivity=84%; Specificity=72% (median) | 15% | 38% | 96%
Risk factor screening by various criteria Sensitivity=84%; Specificity=72% (median) | 25% | 54% | 93%

ADA = American Diabetes Association; CC = Carpenter-Coustan; FPG = fasting plasma glucose; NDDG = National Diabetes Data Group; OGCT = oral glucose challenge test; WHO =World Health Organization

#### Key Question 2

Only two retrospective cohort studies were relevant to Key Question 2, which asked about the direct benefits and harms of screening for GDM. One retrospective cohort study (n=1,000) conducted in Thailand showed a significantly greater incidence of cesarean deliveries in the screened group. A survey of a subset of participants (n=93) in a large prospective cohort study involving 116,678 nurses age 25–42 years in the United States found the incidence of macrosomia (infant weight ≥ 4.3 kg) was the same in the screened and unscreened groups (7 percent each group).

No RCTs were available to answer questions about screening. There is a paucity of evidence on the effect of screening women for GDM on health outcomes. The comparison for this question was women who had and had not undergone screening. Since screening is now commonplace it may be unlikely to identify studies or cohorts in which this comparison is feasible.

#### Key Question 3

Thirty-eight studies provided data for Key Question 3, which sought to examine health outcomes for women who met various criteria for GDM and did not receive treatment. A summary of the results is provided in Table D. The majority of data came from cohort studies or the untreated groups from RCTs. Study quality was assessed using the Newcastle-Ottawa Scale with a possible total of nine stars. The median quality score was 9 out of 9 stars. Studies receiving lower scores most often did not control for potential confounding, and/or had an important proportion of patients lost to followup. Overall, the majority of studies were considered good quality (36 of 38, 95 percent).

A wide variety of diagnostic criteria and thresholds were compared across the studies. The most common groups reported and compared were GDM diagnosed by CC criteria, no GDM by any criteria (normal), impaired glucose tolerance defined as one abnormal glucose value, and false positive (positive OGCT, negative OGTT). Only single studies contributed data for many of the comparisons and outcomes; therefore, results that showed no statistically significant differences between groups cannot be interpreted as equivalence between groups, and they do not rule out potential differences.

Two studies did not group women according to criteria (as above) but examined glucose levels as a continuous outcome and their association with maternal and neonatal outcomes. Both studies were methodologically strong. A continuous positive association was found between maternal glucose and birthweight (both studies), as well as fetal hyperinsulinemia (one study only). There was some evidence of an association between glucose levels and primary cesarean section and neonatal hypoglycemia, although the associations were not consistently significant. No clear glucose thresholds were found that were predictive of poor outcomes. One of these studies also found significantly fewer cases of preeclampsia, cesarean section, shoulder dystocia and/or birth injury, clinical neonatal hypoglycemia, and hyperbilirubinemia for women with no GDM compared with those meeting IADPSG criteria.

For maternal outcomes among the studies that compared groups as described above, women without GDM and those testing false positive showed fewer cases of preeclampsia than those meeting CC criteria. No differences in preeclampsia were found for other comparisons, although evidence was based on few studies per comparison.

Fewer cases of cesarean section were found among women without GDM compared with women meeting criteria for CC GDM, CC 1 abnormal OGTT, CC false positives, NDDG false positives, NDDG 1 abnormal oral glucose tolerance test, WHO IGT, IADPSG impaired fasting glucose (IFG), and IADPSG impaired glucose tolerance (IGT) IFG. There were fewer cases of cesarean section among false positives compared with women meeting criteria for CC GDM. For 12 other comparisons, there were no differences in rates of cesarean delivery.

For maternal hypertension, significant differences were found for 8 of 16 comparisons; many comparisons were based on single studies. No GDM groups showed lower incidence of maternal hypertension when compared with CC GDM, CC 1 abnormal OGTT, IADPSG IFG, IADPSG IGT-2 (double-impaired glucose tolerance), and IADPSG IGT IFG. Other comparisons showing significant differences were CC GDM versus false positives (lower incidence for false positives), IADPSG IGT versus IGT IFG (lower incidence for IGT), and IADPSG IFG versus IGT IFG (lower incidence for IFG).

Based on single studies, no differences were observed for maternal birth trauma for three comparisons. For maternal weight gain (less weight gain considered beneficial), significant differences were found for 3 of 12 comparisons: IADPSG IGT versus no GDM (favored IGT), IADPSG IFG versus no GDM (favored IFG), IADPSG IGT-2 versus no GDM (favored IGT-2). All comparisons were based on single studies. For maternal mortality/morbidity, single studies contributed to three comparisons, and no differences were found except for fewer cases among patient groups with no GDM compared with IADPSG GDM. No studies provided data on long-term maternal outcomes, such as type 2 diabetes mellitus, obesity, and hypertension.

The most commonly reported outcome for the offspring was macrosomia >4,000 g. Six of 11 comparisons showed a significant difference: there were fewer cases in the group without GDM compared with CC GDM, CC 1 abnormal OGTT, NDDG GDM (unrecognized), NDDG false positives, and WHO IGT. Fewer cases were found for women with false-positive results compared with CC GDM. Data for macrosomia >4,500 g were available for four comparisons and showed significant differences in two comparisons: patient groups with no GDM had fewer cases compared with women with CC GDM and with unrecognized NDDG GDM.

For shoulder dystocia, significant differences were found for 7 of 17 comparisons; all but one comparison were based on single studies. Patient groups with no GDM showed lower incidence of shoulder dystocia when compared with CC GDM (5 studies), NDDG GDM (unrecognized), NDDG false positive, WHO IGT, IADPSG IFG, and IADPSG IGT IFG. The other significant difference showed lower incidence among the false-positive group compared with CC 1 abnormal OGTT.

For fetal birth trauma or injury, four studies compared CC GDM, NDDG GDM, and WHO IGT with patient groups without GDM. No differences were observed except for NDDG GDM, which favored the group with no GDM. Only one difference was found for neonatal hypoglycemia, with fewer cases among patient groups without GDM compared with those meeting CC criteria. There were 16 comparisons for hyperbilirubinemia; the majority were based on single studies. Three comparisons showed significant differences between groups: patient groups with no GDM had fewer cases compared with CC false positive, IADPSG IGT, and IADPSG IGT-2, respectively. No differences were found for fetal morbidity/mortality for any of eight comparisons, which may be attributable to small numbers of events within some comparisons. Moreover, comparisons were based on single studies.

Based on a single study, significant differences were found in prevalence of childhood obesity for CC GDM versus patients without GDM (lower prevalence for no GDM) and CC GDM versus false positives (lower prevalence for false positives). This was consistent for both childhood obesity >85^th^ percentile as well as >95^th^ percentile. However, this study was unable to control for maternal weight or BMI, which are established predictors of childhood obesity. No differences, based on the same single study, were found for the other four comparisons within >85^th^ or >95^th^ percentiles. No other studies provided data on long-term outcomes, including type 2 diabetes mellitus and transgenerational GDM.

In summary, different thresholds of glucose intolerance affect maternal and neonatal outcomes of varying clinical importance. While many studies have attempted to measure the association between various criteria for GDM and pregnancy outcomes in the absence of treatment, the ability of a study or pooled analysis to find a statistically significant difference in pregnancy outcomes appears more dependent on study design, in particular the size of the study or pooled analysis, rather than the criteria used for diagnosing GDM. This is not surprising given the strong support found for a continuous positive relationship between glucose and a variety of pregnancy outcomes. The clinical significance of absolute differences in event rates requires consideration by decisionmakers even though statistical significance was reached at the strictest diagnostic glucose thresholds for some outcomes.

This question focused on outcomes for women who did not receive treatment for GDM. While women with untreated GDM have a variety of poorer outcomes than women without GDM, it cannot be assumed that treatment of GDM reverses all the short- and long-term poor outcomes observed in women with untreated GDM. Some of the reasons for the poorer outcomes in women that have untreated GDM may not be modifiable, such as the influences of genetic makeup. The strength of evidence was insufficient for most outcomes and comparisons in this question due to high risk of bias (observational studies), inconsistency across studies, and/or imprecise results. The strength of evidence was low for the following outcomes and comparisons: preeclampsia (CC GDM vs. no GDM, CC GDM vs. false positives), macrosomia >4,000 g (CC GDM vs. no GDM, CC GDM vs. false positives, CC GDM vs. 1 abnormal OGTT, CC false positives vs. no GDM, NDDG false positives vs. no GDM), macrosomia >4,500 g (CC GDM vs. no GDM), and shoulder dystocia (CC GDM vs. no GDM).

#### Key Question 4

Eleven studies provided data for Key Question 4 to assess the effects of treatment for GDM on health outcomes of mothers and offspring. All studies compared diet modification, glucose monitoring, and insulin as needed with standard care. The strength of evidence for key outcomes is summarized in Table C, and a summary of the results is provided in Table D.

Table C Strength of evidence for Key Question 4: maternal and infant outcomes

Outcome | # Studies (# Patients) | Overall Strength of Evidence | Comment
Preeclampsia | 3 RCTs (2,014) | moderate (favors treatment) | The evidence provides moderate confidence that the estimate reflects the true effect in favor of the treatment group.
Preeclampsia | 1 cohort (258) | insufficient | The evidence provides moderate confidence that the estimate reflects the true effect in favor of the treatment group.
Maternal weight gain | 4 RCTs (2,530) | insufficient | There is insufficient evidence to draw conclusions for this outcome due to inconsistency across studies and imprecise effect estimates.
Maternal weight gain | 2 cohorts (515) | insufficient | There is insufficient evidence to draw conclusions for this outcome due to inconsistency across studies and imprecise effect estimates.
Birth injury | 2 RCTs (1,230) | low (no difference) | There is insufficient evidence to make a conclusion for this outcome. There is a difference in findings for the RCTs and cohort studies; the number of events and participants across all studies does not allow for a conclusion.
Birth injury | 1 cohort (389) | insufficient
Shoulder dystocia | 3 RCTs (2,044) | moderate (favors treatment) | The evidence provides moderate confidence that the estimate reflects the true effect in favor of the treatment group.
Shoulder dystocia | 4 cohorts (3,054) | low (favors treatment) | The evidence provides moderate confidence that the estimate reflects the true effect in favor of the treatment group.
Neonatal hypoglycemia | 4 RCTs (2,367) | low (no difference) | The evidence provides low confidence that there is no difference between groups.
Neonatal hypoglycemia | 2 cohorts (2,054) | insufficient | The evidence provides low confidence that there is no difference between groups.
Macrosomia (>4,000 g) | 5 RCTs (2,643) | moderate (favors treatment) | The evidence provides moderate confidence that the estimate reflects the true effect in favor of the treatment group.
Macrosomia (>4,000 g) | 6 cohorts (3,426) | low (favors treatment) | The evidence provides moderate confidence that the estimate reflects the true effect in favor of the treatment group.
Long-term metabolic outcomes: impaired glucose tolerance | 1 RCT (89) | insufficient | There is insufficient evidence to draw conclusions for this outcome.
Long-term metabolic outcomes: type 2 diabetes mellitus | 1 RCT (89) | insufficient | There is insufficient evidence to draw conclusions for this outcome.
Long-term metabolic outcomes: BMI (assessed as >85^th^ and >95^th^ percentile) | 2 RCTs (284) | low (no difference) | The evidence provides low confidence that there is no difference between groups.

BMI = body mass index; RCT = randomized controlled trial

Among the 11 included studies, 5 were RCTs and 6 were cohort studies. The risk of bias for the RCTs was low for one trial, unclear for three trials, and high for one trial. The trials that were unclear most commonly did not report detailed methods for sequence generation and allocation concealment. The trial assessed as high risk of bias was due to lack of blinding for outcome assessment and incomplete outcome data. The six cohort studies were all considered high quality, with overall scores of 7 to 9 on a 9-point scale.

There was moderate evidence showing a significant difference for preeclampsia, with fewer cases in the treated group. There was inconsistency across studies in terms of differences in maternal weight gain, and the strength of evidence was considered insufficient. There were no data on long-term outcomes among women, including type 2 diabetes mellitus, obesity, and hypertension.

In terms of infant outcomes, there was insufficient evidence for birth trauma. This was driven by lack of precision in the effect estimates and inconsistency across studies: there was no difference for RCTs, but a significant difference favoring treatment in the one cohort study. The incidence of shoulder dystocia was significantly lower in the treated groups, and this finding was consistent for the three RCTs and four cohort studies. Overall, the evidence for shoulder dystocia was considered moderate, showing a difference in favor of the treated group. For neonatal hypoglycemia, the strength of evidence was low, suggesting no difference between groups. Moderate evidence showed benefits of treatment in terms of macrosomia (>4,000 g).

Only one study provided data on long-term metabolic outcomes among the offspring at a 7- to 11-year followup. The strength of evidence was insufficient. For both outcomes—impaired glucose tolerance and type 2 diabetes mellitus—no differences were found between groups although the estimates were imprecise. No differences were observed in single studies that assessed BMI >95 (7- to 11-year followup) and BMI >85 percentile (5- to 7-year followup). Overall, pooled results showed no difference in BMI, and the strength of evidence was low.

In summary, there was moderate evidence showing differences in preeclampsia and shoulder dystocia, with fewer cases among women (and offspring) who were treated compared with those not receiving treatment. There was also moderate evidence showing significantly fewer cases of macrosomia (>4,000 g) among offspring of women who received treatment for GDM. The results were driven by the two largest RCTs, the Maternal Fetal Medicine Unit (MFMU)25 and the Australian Carbohydrate Intolerance in Pregnancy Study (ACHOIS),52 which had unclear and low risk of bias, respectively. There was little evidence showing differences between groups in other key maternal and infant outcomes. One potential explanation is that for the most part, the study populations included women whose glucose intolerance was less marked, as those whose glucose intolerance was more pronounced would not have been entered into a trial in which they may be assigned to a group receiving no treatment. For outcomes where results were inconsistent between studies, different study glucose threshold entry criteria did not explain the variation. For some outcomes, particularly the long-term outcomes, the strength of evidence was insufficient or low, suggesting that further research may change the results and increase our confidence in them. Moreover, for some outcomes events were rare, and the studies may not have had the power to detect clinically important differences between groups; therefore, findings of no significant difference should not be interpreted as equivalence between groups.

#### Key Question 5

Five studies (four RCTs and one cohort study) provided data for Key Question 5 on the harms associated with treatment of GDM. Among the four RCTs, one had low and three had unclear risk of bias. The cohort study was high quality (7/9 points); the primary limitation was not controlling for potential confounders.

Four of the studies provided data on the incidence of infants that were small for gestational age and showed no significant difference between groups. This finding may have resulted from inadequate power to detect differences due to a small number of events; therefore, the finding of no significant difference should not be interpreted as equivalence between groups.

Four of the studies provided data on admission to the NICU and showed no significant differences overall. One study was an outlier because it showed a significant difference favoring the no treatment group. This difference may be attributable to site-specific policies and procedures or lack of blinding of investigators to treatment arms. Two studies reported on the number of prenatal visits and generally found significantly more visits between the treatment groups.

Two of the RCTs showed no significant difference overall in the rate of induction of labor, although there was important statistical heterogeneity between studies. One RCT showed significantly more inductions of labor in the treatment group,52 while the other study did not.25 Different study protocols may account for the heterogeneity of results between studies. In the first study that showed more inductions of labor in the treatment group, no recommendations were provided regarding obstetrical care. In the second study, antenatal surveillance was reserved for standard obstetrical indications. Based on the studies included in Key Question 4 (five RCTs and six cohort studies), there was no difference in rates of cesarean section between treatment and nontreatment groups.

A single study assessed depression and anxiety at 6 weeks after study entry and 3 months postpartum using the Spielberger State-Trait Anxiety Inventory and the Edinburgh Postnatal Depression Score, respectively. There was no significant difference in anxiety between the groups at either time point, although there were significantly lower rates of depression in the treatment group at 3 months postpartum. These results should be interpreted cautiously because the assessment of depression and anxiety was conducted in a subgroup of the study population.

There was no evidence for some of the outcomes stipulated in the protocol, including costs and resource allocation.

## Findings in Relationship to What Is Already Known

This review provides evidence that treating GDM reduces some poor maternal and neonatal outcomes. The recent MFMU trial25 published in 2009 reinforces the findings of the earlier ACHOIS trial that was published in 2005^52^ and included in an earlier version of this review.24 Both trials showed that treating GDM to targets of 5.3 or 5.5 mmol/L fasting and 6.7 or 7.0 mmol/L 2 hours postmeal reduced neonatal birthweight, large for gestational age, macrosomia, shoulder dystocia, and preeclampsia, without a reduction in neonatal hypoglycemia or hyperbilirubinemia/jaundice requiring phototherapy, or an increase in small for gestational age. In contrast to the ACHOIS trial, MFMU demonstrated a reduced cesarean section rate in the GDM treatment group. The failure of ACHOIS to find a lower cesarean section rate despite reduced neonatal birthweight and macrosomia may have been the result of differing obstetrical practices or the different populations studied (e.g., the inclusion of some women with more marked glucose intolerance in ACHOIS, as reflected by the increased prevalence of insulin use; more black and Hispanic women in the MFMU study). Differences may have also resulted due to study design: in the ACHOIS trial, participants did not receive specific recommendations regarding obstetrical care, thus treatment was left to the discretion of the delivering health care provider. In the MFMU study, antenatal surveillance was reserved for standard obstetrical indications. Our findings of the effect of treatment of GDM is similar to a systematic review and meta-analysis published in 2010 by Horvath and colleagues.53 This review included two older RCTs of GDM that were not included in our analysis because we restricted our inclusion criteria to studies published after 1995.

The HAPO Study Cooperative Research Group3 used a simpler 75 g OGTT in a large international sample of women and confirmed findings of the earlier Toronto Trihospital study51 that there is a continuous positive association between maternal glucose and increased birthweight, as well as fetal hyperinsulinemia (HAPO only), at levels below diagnostic thresholds for GDM that existed at the time of the study. However, no clear glucose thresholds were found for fetal overgrowth or a variety of other maternal and neonatal outcomes. Subsequently, the IADPSG developed diagnostic thresholds for GDM based on a consensus of expert opinion of what was considered to be the most important outcomes and the degree of acceptable risk for these outcomes. The thresholds chosen by the IADPSG were derived from the HAPO data to identify women with a higher risk (adjusted odds ratio 1.75) of large for gestational age, elevated c-peptide, and high neonatal body fat compared with the mean maternal glucose values of the HAPO study. The glucose threshold chosen by the IADPSG represents differing levels of risk for other outcomes. Specifically, their thresholds represent a 1.4 (1.26–1.56) risk for pregnancy-induced hypertension and a 1.3 (1.07–1.58) risk for shoulder dystocia. A dichotomous view of GDM may no longer be appropriate, given evidence of a continuous relationship between maternal blood glucose and pregnancy outcomes. An alternative approach may be to define different glucose thresholds based on maternal risk for poor pregnancy outcomes. This approach has been used in the context of lipid levels and risk of adverse cardiovascular outcomes.

Neither recent RCT was designed to determine diagnostic thresholds for GDM or therapeutic glucose targets. However, it is noteworthy that therapeutic glucose targets for both ACHOIS and MFMU were above the proposed diagnostic criteria of the IADPSG (fasting 5.5 mmol/L [99 mg/dL] and 5.3 mmol/L [95 mg/dL] and 2 hour postmeal of 7.0 mmol/L [126 mg/dL and 6.7 mmol/L 120 mg/dL], respectively). A change in diagnostic criteria without addressing management thresholds could contribute to clinical confusion. If diagnostic thresholds for GDM below the treatment targets of the large RCTs are endorsed, this could ethically obstruct the possibility of future RCTs to compare different treatment targets above such diagnostic thresholds.

It has been hypothesized that treatment of GDM may reduce future poor metabolic outcomes for children born to mothers with GDM. If true, the potential for long-term gain is important from a clinical and public health perspective and may justify the “costs” of screening and treating women for GDM. However, the followup of offspring from two RCTs52,54 and a HAPO cohort in Belfast 55 currently fail to support this hypothesis. This may be explained in part due to insufficient length of followup or inadequate numbers of events.

The HAPO study showed that maternal weight and glucose predict large for gestational age. However, BMI was the better predictor of large for gestational age than glucose until glucose thresholds higher than the diagnostic thresholds set by the IADPSG were reached.56,57 Most cases of large for gestational age occur in neonates of mothers with normal glycemia. A large observational study found that the upper quartile of maternal BMI accounted for 23 percent of macrosomia, while GDM was responsible for only 3.8 percent.58

The ongoing obesity epidemic in the United States warrants careful consideration of a diagnostic approach for GDM that incorporates maternal BMI. This would require the development and validation of a risk model that incorporates maternal BMI as well as other modifiable risk factors. Such a model could facilitate the identification of women at high risk of adverse pregnancy outcomes and minimize exposure of lower risk women to unnecessary interventions.

## Applicability

Several issues may limit the applicability of the evidence presented in this review to the U.S. population. All of the Key Questions asked about the effects of screening and treatment before and after 24 weeks' gestation. The vast majority of included studies screened women after 24 weeks' gestation; therefore, the results are not applicable to screening and treatment earlier in gestation.

For Key Question 1 on the test properties of screening and diagnostic tests, comparisons involving the WHO criteria are less applicable to the U.S. setting because these criteria are not used in North America. There were insufficient data from the included studies to assess the performance of screening or diagnostic tests for specific patient characteristics (e.g., BMI, race/ethnicity). Therefore it is unclear whether the evidence applies to specific subpopulations of women.

For Key Question 2, limited evidence was identified because the comparison of interest was women who had not undergone screening. Because screening is routine in prenatal care in the United States, the evidence (or limited evidence) is likely not helpful for U.S. decisionmaking, and a refinement of this question may be appropriate to reflect current practices and outstanding questions.

With respect to Key Question 3, all studies or groups included for analysis involved women who had not received treatment for GDM. It cannot be assumed that the same associations and outcomes would be observed in clinical practice in which standard care is to screen for and treat GDM. The untreated women may differ from the general population in ways that are related to the reasons for which they did not seek or receive early prenatal care (e.g., socioeconomic status). That is, the reasons they did not receive treatment for GDM are varied; some reasons, such as late presentation for obstetrical care, may confound the observed association with health outcomes. Attempts were made to control for these factors in some studies (e.g., Langer and colleagues59) by including a group of women without GDM with similar known confounders or by adjusting for known confounders in the analysis. The adjusted estimates did not change the overall pooled results in the majority of cases and did not change the overall conclusions.

The majority of the studies for Key Questions 4 and 5 pertaining to the benefits and harms of treatment for GDM were conducted in North America or Australia. Most of the North American studies were inclusive of mixed racial populations and are likely applicable to the general U.S. population. Even though the Australian RCT52 population had more white women with a lower BMI than the U.S. RCT (MFMU25), this should not affect applicability of most of their findings because these patient characteristics would be factors associated with lower risk of poor outcomes. Differences in physician or hospital billing structures between the United States and Australia may have accounted for the discrepant findings with respect to NICU admissions and, as a result, may limit the applicability of this finding in the United States. Among the studies included in Key Questions 4 and 5, a variety of glucose threshold criteria were used for inclusion, varying from 50 g screen positive with nondiagnostic OGTTs, to women who met NDDG criteria for a diagnosis of GDM. The two large RCTs25,52 used different glucose thresholds for entry in their trials: WHO and CC criteria with a fasting glucose <95 mg/dL (5.3 mmol/L), respectively. The mean glucose levels at study entry were similar between these two RCTs, which may reflect a reluctance to assign women with more marked glucose intolerance to a group receiving no treatment. The results may not be applicable to women with higher levels of glucose intolerance.

## Limitations of the Evidence Base

There is sparse evidence to clarify issues regarding the timing of screening and treatment for GDM (i.e., before and after 24 weeks' gestation). Earlier screening will help identify overt type 2 diabetes mellitus and distinguish this from GDM. This has important implications for clinical management and ongoing followup beyond pregnancy. Previously unrecognized type 2 diabetes mellitus diagnosed in pregnancy should be excluded from the diagnosis of GDM because this condition has the highest perinatal mortality rate of all classes of glucose intolerance in pregnancy.60 This distinction within research studies will provide more targeted evidence to help obstetrical care providers to risk stratify obstetrical care and glycemic management of patients with overt type 2 diabetes mellitus diagnosed in pregnancy and those with less pronounced pregnancy-induced glucose intolerance. This will also facilitate better comparability across future studies. Few data were available on long-term outcomes. Furthermore, the studies included in this review do not provide evidence of a direct link between short-term and long-term outcomes (e.g., macrosomia and childhood obesity).

Care provider knowledge of the glucose screening and diagnostic results may have introduced a bias if their subsequent treatment of women differed depending on the results. This was of particular concern for Key Question 3, which assessed how the various criteria for GDM influenced pregnancy outcomes. For Key Question 3, many of the statistically significant differences seemed to be driven by the size of the study or pooled analysis (i.e., statistically significant differences could be found if the sample were sufficiently large). However, these differences may not be clinically important. The absolute differences in event rates between different glucose thresholds need careful consideration by decisionmakers, even though statistically significant differences were found. Another key limitation with the evidence for Key Question 3 is that the studies included were cohort studies, many of which did not control for potential confounders. Therefore, any associations between glucose thresholds and outcomes should be interpreted with caution.

Given that the large landmark studies51,61 show a continuous relationship between glucose and maternal and neonatal outcomes, the lack of clear thresholds contributes to the uncertainty regarding a diagnostic threshold for GDM. While there is controversy about where to set lower limits for diagnostic criteria, the identification of overt diabetes in pregnancy is imperative if this diagnosis has not occurred before pregnancy. Overt diabetes first identified in pregnancy should be distinguished from GDM to gain a better understanding of the true risk of GDM to pregnancy outcomes. Unfortunately there is no literature to guide diagnostic criteria for a diagnosis of overt diabetes in pregnancy.

There were several methodological concerns for this evidence base. For example, risk of spectrum bias and partial verification bias (Key Question 1); different definitions or methods of assessing key outcomes (e.g., clinical vs. biochemical neonatal hypoglycemia and hyperbilirubinemia) (Key Questions 3 and 4); and lack of blinding of treatment arms in some studies (Key Questions 4 and 5).

## Future Research

Several important gaps in the current literature exist:

- The adoption of a consistent comparator for diagnosis of GDM, such as the 75 g OGTT, would facilitate comparisons across studies even if different diagnostic thresholds are used.
- Further analysis of the HAPO data could help answer some outstanding questions. For example, further analysis could better define absolute differences in rare event rates. This evidence could be used to inform discussions about the clinical importance of absolute differences in event rates at thresholds other than those of the IADPSG. Such analyses should include adjustment for important confounders such as maternal BMI.
- Further analysis of the HAPO data, examining center-to-center differences in glucose outcome relationships would be helpful in determining the usefulness of FPG as a screening test for GDM.
- Research is needed to clarify issues regarding earlier screening and treatment, particularly as they relate to the diagnosis, treatment, and long-term outcomes of pregestational (overt) diabetes.
- Further research of FPG, a screening test, is needed, given that the reproducibility of fasting glucose measurement is superior to postglucose load measurements.62
- Further study of the long-term metabolic outcomes in offspring whose mothers have been treated for GDM is warranted. In addition, data on the influences of GDM treatment on long-term breastfeeding success have not been studied. The association of breastfeeding with reduced poor metabolic outcomes in offspring of GDM has been found to have a dose-dependent response with duration of breastfeeding.63
- Implementation of well-conducted prospective cohort studies of the “real world” effects of GDM treatment on use of care is needed.
- Research on outcomes is needed to help determine the glucose thresholds and treatment targets at which GDM treatment benefits outweigh the risks of treatment and no treatment. This will best be achieved through well-conducted, large RCTs that randomize women with GDM to different glucose treatment targets.
- While this review did not identify evidence of substantial harms to treatment, the populations considered were mostly women whose GDM was controlled without medication. There is a risk for more precautionary management of women diagnosed with GDM, who are perceived by clinicians to be at greater risk, such as those managed with insulin, which may result in unnecessary interventions (e.g., cesarean section).64 Therefore, RCTs investigating the care of women diagnosed with GDM, including fetal surveillance protocols, are needed to guide obstetrical investigations and management of GDM. Further, RCTs comparing delivery management for GDM with and without insulin or medical management are needed to provide clinicians guidance on appropriate timing and management of delivery in women with GDM to avoid unnecessary intervention in “the real world” driven by health care provider apprehension.
- The development of long-term studies that evaluate the potential increased or decreased resource use associated with the implementation of diabetes prevention strategies after a diagnosis of GDM is required.
- Studies to assess the long-term results that a label of GDM may have for future pregnancy planning, future pregnancy management, and future insurability are required.
- The increased prevalence of type 2 diabetes mellitus in women of reproductive age merits consideration of preconception screening for overt diabetes in women at risk of type 2 diabetes. In addition to poor maternal and neonatal outcomes associated with overt diabetes in pregnancy, there is potential for benefit of preconception care.
- Long-term benefits and harms need to be evaluated among different treatment modalities for GDM (e.g., diet, exercise, insulin, oral glucose-lowering medications, and/or combinations of these).
- Since 2011–2012, the American Diabetes Association has endorsed the use of an HbA1c of 6.5 percent or more as a diagnostic of diabetes in nonpregnant women.36 Studies of HbA1c with trimester-specific cutoffs to determine the value at which overt diabetes should be diagnosed in pregnancy are needed.

## Limitations of the Review

This review followed rigorous methodological standards, which were detailed a priori. The limitations of the review to fully answer the Key Questions are largely due to the nature and limitations of the existing evidence.

Several limitations need to be discussed regarding systematic reviews in general. First, there is a possibility of publication bias. The effects of publication bias on the results of diagnostic test accuracy reviews (Key Question 1) is not well understood, and the tools to investigate publication bias in these reviews have not been developed. For the remaining Key Questions, we may be missing unpublished and/or negative therapy studies and may be overestimating the benefits of certain approaches. However, we conducted a comprehensive and systematic search of the published literature for potentially relevant studies. Search strategies included combinations of subject headings and free text words. These searches were supplemented by handsearching for gray literature (i.e., unpublished or difficult-to-find studies). Despite these efforts, we recognize that we may have missed some studies.

There is also a possibility of study selection bias. However, we employed at least two independent reviewers and feel confident that the studies excluded from this report were done so for consistent and appropriate reasons. Our search was comprehensive, so it is unlikely that many studies in press or publication were missed.

Cost analysis of different screening and diagnostic approaches was not addressed in this review.

## Conclusions

There was limited evidence regarding the test characteristics of current screening and diagnostic strategies for GDM. Lack of an agreed-upon gold standard for diagnosing GDM creates challenges for assessing the accuracy of tests and comparing across studies. The 50 g OGCT with a glucose threshold of 130 mg/dL versus 140 mg/dL improves sensitivity and reduces specificity (10 studies). Both thresholds have high negative predictive value, but variable positive predictive value across a range of GDM prevalence. There was limited evidence for the screening of GDM diagnosed less than 24 weeks' gestation (3 studies). Single studies compared the diagnostic characteristics of different pairs of diagnostic criteria in the same population. The use of fasting glucose (≥85 mg/dL) as a screen for GDM may be a practical alternative because of similar test characteristics to the OGCT, particularly in women who cannot tolerate any form of oral glucose load.

Evidence supports benefits of treating GDM, with little evidence of short-term harm. Specifically, treatment of GDM results in lower incidence of preeclampsia, macrosomia, and large for gestational age infants. Current research does not demonstrate a treatment effect of GDM on clinical neonatal hypoglycemia or future poor metabolic outcomes of the offspring. RCTs of GDM treatment show limited harm related to treating GDM, other than an increased demand for services. There is a risk for more precautionary management of women diagnosed with GDM, who are perceived by clinicians to be at greater risk, such as those managed with insulin, which may result in unnecessary interventions (e.g., cesarean section); however, this review found limited data for these outcomes, and further research on the care of women diagnosed with GDM (e.g., fetal surveillance protocols) is warranted.

What remains less clear is what the lower limit diagnostic thresholds for GDM should be. Given the continuous association between glucose and a variety of outcomes, decisions should be made in light of what outcomes altered by treatment are the most important and what level of increased risk is acceptable. A dichotomous view of GDM may no longer be appropriate, given evidence of a continuous relationship between maternal blood glucose and pregnancy outcomes. An alternative approach would be to define different glucose thresholds based on maternal risk for poor pregnancy outcomes.

Further study is needed regarding the long-term metabolic outcomes on offspring of mothers receiving GDM treatment; the “real world” impact of GDM treatment on use of care outside of structured research trials; and the results of the timing of screening for GDM, particularly before 24 weeks' gestation and in the first trimester of pregnancy. Early screening could help identify pregestational (i.e., overt) diabetes. Research is urgently required to determine the best way to diagnose and manage overt diabetes in pregnancy, particularly in an era of increasing rates of obesity and diabetes in the U.S. population.

## References

1 Balsells M, Garcia-Patterson A, Gich I, et al. Maternal and fetal outcome in women with type 2 versus type 1 diabetes mellitus: a systematic review and metaanalysis. J Clin Endocrinol Metab. 2009;94(11):4284-91. [pmid: 19808847].
2 National Diabetes Data Group. Diabetes in America. 2nd ed. Bethesda, MD. National Institutes of Health. 1995.
3 HAPO Study Cooperative Research Group, Metzger B, Lowe L, et al. Hyperglycemia and adverse pregnancy outcomes. N Engl J Med. 2008;358(19):1991-2002. [pmid: 18463375].
4 American Diabetes Association. Position statement: standards of medical care in diabetes - 2012. Diabetes Care. 2012;35(Suppl 1):S11-S63. [pmid: 22187469].
5 Carpenter MW, Coustan DR. Criteria for screening tests for gestational diabetes. Am J Obstet Gynecol. 1982;144(7):768-73. [pmid: 7148898].
6 Sacks DA, Hadden DR, Maresh M, et al. Frequency of gestational diabetes mellitus at collaborating centers based on IADPSG consensus panel-recommended criteria: the Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. Diabetes Care. 2012;35(3):526-8. [pmid: 22355019].
7 Ferrara A. Increasing prevalence of gestational diabetes mellitus: a public health perspective. Diabetes Care. 2007;30(Suppl 2):S141-S146. [pmid: 17596462].
8 Gillman MW, Oakey H, Baghurst PA, et al. Effect of treatment of gestational diabetes mellitus on obesity in the next generation. Diabetes Care. 2010;33(5):964-8. [pmid: 20150300].
9 Kaufmann RC, Schleyhahn FT, Huffman DG, et al. Gestational diabetes diagnostic criteria: long-term maternal follow-up. Am J Obstet Gynecol. 1995;172(2 Pt 1):621-5. [pmid: 7856695].
10 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2006;29(Suppl 1):S43-S48. [pmid: 16373932].
11 Berger H, Crane J, Farine D, et al. Screening for gestational diabetes mellitus. J Obstet Gynaecol Can. 2002;24(11):894-912. [pmid: 12417905].
12 Naylor CD, Sermer M, Chen E, et al. Selective screening for gestational diabetes mellitus. Toronto Trihospital Gestational Diabetes Project Investigators. N Engl J Med. 1997;337(22):1591-6. [pmid: 9371855].
13 Hillier T, Vesco K, Pedula K, et al. Screening for gestational diabetes mellitus: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2008;148:766-75. [pmid: 18490689].
14 American College of Obstetricians and Gynecologists Committee on Practice Bulletins. ACOG Practice Bulletin. Clinical management guidelines for obstetrician-gynecologists. Number 30, September 2001. Gestational Diabetes. Obstet Gynecol. 2001;98(3):525-38. [pmid: 11547793].
15 Meltzer SJ, Snyder J, Penrod JR, et al. Gestational diabetes mellitus screening and diagnosis: a prospective randomised controlled trial comparing costs of one-step and two-step methods. BJOG. 2010;117(4):407-15. [pmid: 20105163].
16 Gabbe S, Gregory R, Power M, et al. Management of diabetes mellitus by obstetrician-gynecologists. Obstet Gynecol. 2004;103(6):1229-34. [pmid: 15172857].
17 American Diabetes Association. Position Statement: Diabetes mellitus. Diabetes Care. 2004;27(Suppl 1):S11-S14. [pmid: 14693922].
18 Moses RG, Cheung NW. Point: universal screening for gestational diabetes mellitus. Diabetes Care. 2009;32(7):1349-51. [pmid: 19564479].
19 Danilenko-Dixon DR, Van Winter JT, Nelson RL, et al. Universal versus selective gestational diabetes screening: application of 1997 American Diabetes Association recommendations. Am J Obstet Gynecol. 1999;181(4):798-802. [pmid: 10521732].
20 Berger H, Sermer M. Counterpoint: selective screening for gestational diabetes mellitus. Diabetes Care. 2009;32(7):1352-4. [pmid: 19564480].
21 Metzger B, Gabbe S, Persson B, et al. International Association of Diabetes and Pregnancy Study Groups recommendations on the diagnosis and classification of hyperglycemia in pregnancy. Diabetes Care. 2010;33(3):676-82. [pmid: 20190296].
22 Lipscombe LL, Hux JE. Trends in diabetes prevalence, incidence, and mortality in Ontario, Canada 1995-2005: a population-based study. Lancet. 2007;369(9563):750-6. [pmid: 17336651].
23 American Diabetes Association. Position statement: gestational diabetes mellitus. Diabetes Care. 2003;26(Suppl 1):S103-S105. [pmid: 12502631].
24 U.S.Preventive Services Task Force. Screening for gestational diabetes mellitus: recommendations and rationale. Obstet Gynecol. 2003;101(393):395. [pmid: 12576265].
25 Landon MB, Spong CY, Thom E, et al. A multicenter, randomized trial of treatment for mild gestational diabetes. N Engl J Med. 2009;361(14):1339-48. [pmid: 19797280].
26 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 1999;22(Suppl 1):S5-S19.
27 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2000;23(Suppl 1):S4-S19. [pmid: 12017675].
28 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2001;24(Suppl 1):S5-S20.
29 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2002;25(Suppl 1):S5-S20.
30 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 2003;26(Suppl 1):S5-S20. [pmid: 12502614].
31 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. Jan. 2004;27(Suppl 1):S5-S10. [pmid: 14693921].
32 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2005;28(Suppl 1):S37-S42. [pmid: 15618111].
33 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. Jan. 2007;30(Suppl 1):S42-S7. [pmid: 17192378].
34 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2008;31(Suppl 1):S55-S60. [pmid: 18165338].
35 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2009;32(Suppl 1):S62-S67. [pmid: 19118289].
36 Diagnosis and classification of diabetes mellitus. Diabetes Care. 2010;33(Suppl 1):S62-S69. [pmid: 20042775].
37 International association of diabetes and pregnancy study groups recommendations on the diagnosis and classification of hyperglycemia in pregnancy. Diabetes Care. 2010;33(3):676-82. [pmid: 20190296].
38 Jovanovic L. American Diabetes Association's Fourth International Workshop-Conference on Gestational Diabetes Mellitus: summary and discussion. Therapeutic interventions. Diabetes Care. 1998;21(Suppl 2):B131-37. [pmid: 9704240].
39 Metzger BE, Oats JN, Kjos SL, et al. Summary and Recommendations of the Fifth International Workshop-Conference on Gestational Diabetes Mellitus. Diabetes Care. 2007;30(Suppl 2):S251-S260. [pmid: 17596481].
40 Classification and diagnosis of diabetes mellitus and other categories of glucose intolerance. National Diabetes Data Group. Diabetes. 1979;28(12):1039-57. [pmid: 510803].
41 World Health Organization. Definition, diagnosis and classification of diabetes mellitus and its complications. Report of a WHO Consultation. Part 1: Diagnosis and classification of diabetes mellitus. 1999.
42 World Health Organization. Report of a WHO study Group (Technical Report Series No.727). Report of a WHO study group (Technical Report Series No. 727). 1985.
43 Canadian Diabetes Association Clinical Practice Guidelines Expert Committee. Canadian Diabetes Association 2003 Clinical Practice Guidelines for the Prevention and Management of Diabetes in Canada. Can J Diabetes. 2003;27(Suppl 2):S1-S152.
44 Canadian Diabetes Association 2008 Clinical Practice Guidelines for the Prevention and Management of Diabetes in Canada [corrected]. [published erratum appears in Can J Diabetes 2009 Mar;33(1):46]. Can J Diabetes. 2008;32:iv.
45 Sempowski IP, Houlden RL. Managing diabetes during pregnancy. Guide for family physicians. Canadian Family Physician Médecin De Famille Canadien. 2003;49:761-7. [pmid: 12836864].
46 Metzger BE. Summary and recommendations of the Third International Workshop-Conference on Gestational Diabetes Mellitus. Diabetes. 1991;40(Suppl 2):197-201. [pmid: 1748259].
47 Hoffman L, Nolan C, Wilson JD, et al. Gestational diabetes mellitus--management guidelines. The Australasian Diabetes in Pregnancy Society. The Medical Journal Of Australia. 1998;169(2):93-7. [pmid: 9700346].
48 Brown CJ, Dawson A, Dodds R, et al. Report of the Pregnancy and Neonatal Care Group. Diabetic Medicine: A Journal Of The British Diabetic Association. 1996;13(9 Suppl 4):S43-S53. [pmid: 8894455].
49 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
50 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58(10):982-90. [pmid: 16168343].
51 Sermer M, Naylor CD, Gare DJ, et al. Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1995;173(1):146-56. [pmid: 7631672].
52 Crowther CA, Hiller JE, Moss JR, et al. Effect of treatment of gestational diabetes mellitus on pregnancy outcomes. N Engl J Med. 2005;352(24):2477-86. [pmid: 15951574].
53 Horvath K, Koch K, Jeitler K, et al. Effects of treatment in women with gestational diabetes mellitus: systematic review and meta-analysis. BMJ: British Medical Journal (International Edition). 2010;340:c1395. [pmid: 20360215].
54 Malcolm JC, Lawson ML, Gaboury I, et al. Glucose tolerance of offspring of mother with gestational diabetes mellitus in a low-risk population. Diabetic Med. 2006;23(5):565-70. [pmid: 16681566].
55 Pettitt DJ, McKenna S, McLaughlin C, et al. Maternal glucose at 28 weeks of gestation is not associated with obesity in 2-year-old offspring: The Belfast Hyperglycemia and Adverse Pregnancy Outcome (HAPO) family study. Diabetes Care. 2010;33(6):1219-23. [pmid: 20215449].
56 Ryan EA. Diagnosing gestational diabetes. Diabetologia. 2011;54(3):480-6. [pmid: 21203743].
57 HAPO Study Cooperative Research Group. Hyperglycaemia and Adverse Pregnancy Outcome (HAPO) Study: associations with maternal body mass index. BJOG. 2010;117(5):575-84. [pmid: 20089115].
58 Ricart W, Lopez J, Mozas J, et al. Body mass index has a greater impact on pregnancy outcomes than gestational hyperglycaemia. Diabetologia. 2005;48(9):1736-42. [pmid: 16052327].
59 Langer O, Yogev Y, Most O, et al. Gestational diabetes: the consequences of not treating. Am J Obstet Gynecol. 2005;192(4):989-97. [pmid: 15846171].
60 Cundy T, Gamble G, Townend K, et al. Perinatal mortality in Type 2 diabetes mellitus. Diabet Med. 2000;17(1):33-9. [pmid: 10691157].
61 Sacks DA, Greenspoon JS, bu-Fadil S, et al. Toward universal criteria for gestational diabetes: The 75-gram glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1995;172(2 I):607-14. [pmid: 7856693].
62 Rasmussen SS, Glumer C, Sandbaek A, et al. Short-term reproducibility of impaired fasting glycaemia, impaired glucose tolerance and diabetes The ADDITION study, DK. Diabetes Res Clin Pract. 2008;80(1):146-52. [pmid: 18082284].
63 Schaefer-Graf UM, Hartmann R, Pawliczak J, et al. Association of breast-feeding and early childhood overweight in children from mothers with gestational diabetes mellitus. Diabetes Care. 2006;29(5):1105-7. [pmid: 16644645].
64 Buchanan TA, Kjos SL, Montoro MN, et al. Use of fetal ultrasound to select metabolic therapy for pregnancies complicated by mild gestational diabetes. Diabetes Care. 1994;17(4):275-83. [pmid: 8026282].