# Discussion

## Key Findings and Discussion

Key findings are presented by Key Question in the sections that follow. A summary of the results for all Key Questions is provided in Table 24.

Table 24 Summary of Evidence for all Key Questions

Key Question | Number and Quality of Studies | Limitations/Consistency | Applicability | Summary of Findings
KQ1. What are the sensitivities, specificities, reliabilities, and yields of current screening tests for GDM? (A) After 24 weeks' gestation? (B) During the first trimester and up to 24 weeks' gestation? | A) After 24 wk gestation 51 prospective studies Fair to good quality | Limitations: Lack of an agreed upon gold standard for diagnosis of GDM creates challenges for assessing the accuracy of tests and comparing across studies. GDM was confirmed using criteria developed by CC, ADA, NDDG, and WHO. There were sparse data comparing overall approaches for diagnosis and screening, e.g., one-step vs. two-step, selective vs. universal. Consistency: Across studies, numerous tests and thresholds were examined. Screening tests included the 50 g OGCT, FPG risk factor-based screening, and other less common tests such as HbA1c, serum fructosamine. | Prevalence of GDM varied across studies and diagnostic criteria used. Results need to be interpreted in the context of prevalence. Comparisons involving WHO criteria are less applicable to the North American setting because these criteria are not used in North America. | - Prevalence varied across studies and diagnostic criteria: ADA 2000-2010 (75 g) 2.0 to 19% (range), CC 3.6 to 38%, NDDG 1.4 to 50%, WHO 2 to 24.5%.; - 9 studies examined a 50 g OGCT with a cutoff value of ≥140 mg/dL; GDM was confirmed using CC criteria. Results: sensitivity 85%, specificity 86%, prevalence 3.8 to 31.9%, PPV 18 to 27% (prevalence <10), PPV 32 to 83% (prevalence ≥10), NPV median 98%.; - 6 studies examined a 50 g OGCT (≥130 mg/dL); GDM was confirmed using CC criteria. Results: sensitivity 99%, specificity 77%, prevalence 4.3 to 29.5%, PPV 11 to 31% (prevalence <10), PPV 31 to 62% (prevalence ≥10), NPV median 100%.; - 1 study examined a 50 g OGCT (≥200 mg/dL); GDM was confirmed using CC criteria. Sensitivity, specificity, PPV, and NPV were all 100%. Prevalence was 6.4%.; - 7 studies examined a 50 g OGCT (≥140 mg/dL); GDM was confirmed using NDDG criteria. Results: sensitivity 85%, specificity 83%, prevalence 1.4 to 45.8%, PPV 12 to 39% (prevalence <10), PPV 57% (prevalence ≥10), NPV median 99%.; - 3 studies examined a 50 g OGCT (≥130 mg/dL); GDM was confirmed using NDDG criteria. Results: sensitivity 67 to 90% (range), specificity 47 to 84%, prevalence 16.7 to 35.3%, PPV 20 to 75%, NPV 86 to 95%.; - 3 studies examined a 50 g OGCT (different thresholds); GDM was confirmed using ADA 2000-2010 (75 g) criteria. Prevalence was 1.6 to 4.1 (range). Results: sensitivity 86 to 97% (range), specificity 79 to 87%, PPV 7 to 20%, NPV 99 to 100%.; - 3 studies examined a 50 g OGCT (≥140 mg/dL); GDM was confirmed using WHO criteria. Results: sensitivity 43 to 85%, specificity 73 to 94%, prevalence 3.7 to 15.7%, PPV 18 to 20% (prevalence <10), PPV 58% (prevalence ≥10), NPV median 99%.; - 7 studies examined FPG at different thresholds; GDM was confirmed using CC criteria. Results: at ≥85 mg/dL sensitivity 87%, specificity 52%; at ≥90 mg/dL sensitivity 77%, specificity 76%; at ≥92 mg/dL sensitivity 76%, specificity 92%; at ≥95 mg/dL sensitivity 54%, specificity 93%. At ≥85 mg/dL prevalence 1.4 to 34.53 (range). PPV 10% (prevalence <10) and 23 to 59% (prevalence ≥10). Median NPV 93%.; - 8 studies examined risk factor-based screening but were not pooled. Studies used different criteria to confirm GDM. Results: sensitivity 48 to 95% (range), specificity 22 to 94%, prevalence 1.7 to 16.9%, PPV 5 to 19% (prevalence <10), PPV 20% (prevalence ≥10), NPV median 99%.; - 1 study compared IADPSG vs. ADIPS 2 step (reference) to diagnose GDM. Results: sensitivity 82%, specificity 94%, prevalence 13.0%, PPV 61%, NPV 98%.; - 4 studies compared 75 g and 100 g load tests to diagnose GDM. Prevalence ranged from 1.4 to 50%. Results were not pooled: sensitivity 18 to 100%, specificity 86 to 100%, PPV 12 to 100%, NPV 62 to 100%.
| (B) During the first trimester and up to 24 wk gestation 3 prospective cohort studies | Limitations: Only 3 studies of women before 24 wks gestation; therefore, no conclusions can be made for test characteristics in early pregnancy. Consistency: Not applicable (not enough studies addressing the same question to judge consistency). | Evidence too limited to judge applicability. | - 1 study examined the 50 g OGCT at 10 wks and confirmed GDM using JSOG criteria (75 g). Results: sensitivity 88%, specificity 79%, prevalence 1.6%, PPV 7%, NPV 100%.; - 1 study examined 50 g OGCT at 20 wks and confirmed GDM using ADA (2000-2010) 100 g criteria. Results: sensitivity 56%, specificity 94%, prevalence 3.6%, PPV 24%, NPV 98%.; - 1 study compared 1^st^ and 2^nd^ trimester results using 3 screening tests (OGCT at ≥130 mg/dL, FPG, HbA1c); GDM confirmed using JSOG criteria. Results (OGCT) 1^st^ trimester: prevalence 1.9%, sensitivity 93%, specificity 77%, PPV 7.1, NPV 99%; 2^nd^ trimester: prevalence 2.9%, sensitivity 100%, specificity 85%, PPV 17%, NPV 100%.
KQ2: What is the direct evidence on the benefits and harms of screening women (before and after 24 weeks' gestation) for GDM to reduce maternal, fetal, and infant morbidity and mortality? | 2 retrospective cohort studies Fair and good quality | Limitations: No RCTs available to answer this question. Consistency: Not applicable (not enough studies addressing the same question to judge consistency). | The comparison for this question was women who had and had not undergone screening. Since screening is now commonplace it may be unlikely to identify studies or cohorts where this comparison is feasible. | - 1 study (n=1,000) showed more cesarean deliveries in the screened group. A second study (n=93) found the incidence of macrosomia (≥4.3 kg) was the same in screened and unscreened groups (7% each group).; - Based on the small number of studies and sample sizes, the effect of screening women for GDM on health outcomes is inconclusive.
KQ3: In the absence of treatment, how do health outcomes of mothers who meet various criteria for GDM and their offspring compare to those who do not meet the various criteria? | 38 prospective or retrospective cohort studies; 2 studies were long-term followup from RCTs; however, only data from the untreated patients were included. Fair to good quality | Limitations: Strength of evidence was low to insufficient for all graded outcomes due to risk of bias (all observational studies), inconsistency, and/or imprecision. For many comparisons, the numbers of studies, participants, and/or events was low; therefore, findings of no statistically significant differences between groups do not imply equivalence or rule out potential differences. Consistency: A wide variety of diagnostic criteria and thresholds were compared across studies. There were often few studies with similar comparison groups. Differences in defining and assessing outcomes may have contributed to heterogeneity in results across studies (e.g., biochemical vs. clinical assessment of neonatal hypoglycemia). | All studies or groups included for analysis involved women who had not received treatment for GDM. These women may differ from the general population in other ways that are related to the reasons that they did not seek or receive early prenatal care (e.g., socioeconomic status). | Maternal outcomes:; - A methodologically strong study showed a continuous positive relationship between increasing glucose levels and the incidence of primary cesarean section. This study also found significantly fewer cases of preeclampsia and cesarean section for women with no GDM vs. IADPSG.; - For preeclampsia, significant differences were found for CC vs. patients with no GDM (3 studies), with fewer cases among the patients with no GDM, and for CC vs. false-positive groups (2 studies), with fewer cases among the false positives. The strength of evidence was low. No differences were found for NDDG false positive (2 studies), NDDG 1 abnormal OGTT vs. no GDM (1 study), or IGT WHO vs. no GDM (3 studies); the strength of evidence was insufficient.; - For maternal weight gain, significant differences were found for 3 of 12 comparisons: IADPSG IGT vs. no GDM (favored IGT), IADPSG IFG vs. no GDM (favored IFG), IADPSG IGT-2 vs. no GDM (favored IGT-2). All comparisons were based on single studies (strength of evidence insufficient).; Fetal/neonatal/child outcomes:; - 2 methodologically strong studies showed a continuous positive relationship between increasing glucose levels and the incidence of macrosomia. 1 of these studies also showed significantly fewer cases of shoulder dystocia and/or birth injury, clinical neonatal hypoglycemia, and hyperbilirubinemia for women with no GDM vs. IADPSG.; - For macrosomia >4,000 g, 6 of 11 comparisons showed a significant difference: patient groups with no GDM had fewer cases compared with CC GDM (10 studies), CC 1 abnormal OGTT (7 studies), NDDG GDM (unrecognized) (1 study), NDDG false positives (4 studies), and WHO IGT (1 study). Fewer cases were found for women with false-positive results compared with CC GDM (5 studies). Data for macrosomia >4,500 g were available for 4 comparisons and showed significant differences in 2 cases: patient groups with no GDM had fewer cases compared with CC GDM (3 studies) and unrecognized NDDG GDM (1 study). The strength of evidence for macrosomia was low to insufficient.; - For shoulder dystocia, significant differences were found for 7 of 17 comparisons; all comparisons but 1 were based on single studies (insufficient strength of evidence). Patient groups with no GDM showed lower incidence of shoulder dystocia when compared with CC GDM (5 studies, low strength of evidence), NDDG GDM (unrecognized), NDDG false positive, WHO IGT, IADPSG IFG, and IADPSG IGT IFG. The other significant difference showed lower incidence among the false-positive group compared with CC 1 abnormal OGTT.; - For fetal birth trauma/injury, single studies compared CC GDM and WHO IGT with no GDM and showed no differences. Two studies showed fewer cases for no GDM compared with NDDG GDM. Strength of evidence was insufficient for all comparisons.; - No differences were found for neonatal hypoglycemia for any comparison, including CC GDM vs. no GDM (3 studies), CC GDM vs. 1 abnormal OGTT (1 study), CC 1 abnormal OGTT vs. no GDM (4 studies), NDDG GDM vs. no GDM (1 study), NDDG false positive vs. no GDM (1 study), and WHO IGT vs. no GDM (3 studies). Strength of evidence was insufficient for all comparisons.
KQ4: Does treatment modify the health outcomes of mothers who meet various criteria for GDM and offspring? | 5 RCTs and 6 retrospective cohort studies. Poor to good quality | Limitations: For some outcomes, particularly the long-term outcomes, the strength of evidence was insufficient or low. Moreover, for some outcomes events were rare and the studies may not have had the power to detect clinically important differences between groups; therefore, findings of no significant difference should not be interpreted as equivalence between groups. Consistency: Some inconsistency occurred at 2 levels. First, there were inconsistencies for some outcomes between RCTs and observational studies which may be attributable to confounding and methods of selecting study groups (e.g.,historical control groups). Second, in some instances there were inconsistencies across studies within designs that were often attributable to the manner in which outcomes were defined or assessed (e.g., clinical vs. biochemical assessment of neonatal hypoglycemia). | For the most part, study populations included women whose glucose intolerance was less marked, as those whose glucose intolerance was more pronounced would not be entered into a trial in which they may be assigned to a group receiving no treatment. The majority of studies were conducted in North America or Australia, with 2 from Italy. Most of the North American studies were inclusive of mixed racial populations and are likely applicable to the general U.S. population. Even though the Australian RCT population had more white women with a lower BMI than the U.S. RCT; this should not affect applicability of most of their findings for the U.S. women because these subject characteristics would be factors associated with lower risk of poor outcomes. | Maternal outcomes:; - Moderate evidence from 3 RCTs showed a significant difference for preeclampsia, with fewer cases in the treated group.; - There was inconsistency across studies in terms of maternal weight gain (4 RCTs and 2 cohort studies); the strength of evidence was insufficient due to inconsistency and imprecision in effect estimates.; Offspring outcomes:; - There was insufficient evidence to make a conclusion for birth injury. There was inconsistency across studies with the 2 RCTs showing no difference and the 1 cohort study showing a difference in favor of the treated group. The low number of events and participants across all studies resulted in imprecise estimates.; - Moderate evidence showed significantly lower incidence of shoulder dystocia in the treated groups, and this finding was consistent for the 3 RCTs and 4 cohort studies.; - There was low evidence of no difference between groups for neonatal hypoglycemia based on 4 RCTs and 2 cohort studies.; - For outcomes related to birthweight (including macrosomia >4,000 g, macrosomia >4,500 g, actual birthweight, and large for gestational age), differences were often observed favoring the treated groups. Strength of evidence was moderate for macrosomia >4,000 g.; - 1 RCT followed patients for 7 to 11 years and found no differences for impaired glucose tolerance or type 2 DM, although the strength of evidence was considered insufficient.; - No differences were observed in single studies that assessed BMI >95 (7-11 year followup) and BMI >85 percentile (5-7 year followup). Overall, pooled results showed no difference in BMI, and the strength of evidence was considered low.
KQ5: What are the harms of treating GDM and do they vary by diagnostic approach? | 4 RCTs and 1 retrospective cohort study. Fair to good quality | Limitations: No study evaluated costs and resource allocation. Limited evidence on harms. Limited evidence for number of prenatal visits and NICU admissions. Findings of no significant differences may be attributable to low power and should not be interpreted as equivalence. Consistency: Not applicable (not enough studies addressing the same question to judge). | As above for KQ4. In addition, differences in billing structures between the United States and Australia may have accounted for the discrepant findings with respect to NICU admissions between these studies and as a result limit the applicability of this finding in the United States. | - 1 RCT assessed depression and anxiety at 6 weeks after study entry and 3 months postpartum.; - There was no significant difference between groups in anxiety at either time point, although there were significantly lower rates of depression in the treatment group at 3 months postpartum.; - 4 RCTs reported small for gestational age and found no significant difference.3 RCTs and 1 cohort study provided data on admission to NICU and showed no significant differences overall. One trial was an outlier because it showed a significant difference favoring the no treatment group. This difference may be attributable to site-specific policies and procedures.; - 2 RCTs reported on the number of sprenatal visits and generally found more visits among the treatment groups.; - 2 RCTs reporting on induction of labor showed different results, with 1 showing a significant difference with more cases in the treatment group and the other showing no difference.; - Based on studies included in KQ4, no differences between groups were found for cesarean section (5 RCTs, 6 cohorts) or unplanned cesarean section (1 RCT, 1 cohort).

ADA = American Diabetes Association; ADIPS = Australasian Diabetes in Pregnancy Society; BMI = body mass index; CC = Carpenter-Coustan; DM = diabetes mellitus; FPG = fasting plasma glucose; GDM = gestational diabetes mellitus; HbA1c = glycated hemoglobin; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; IGT-2 = double impaired glucose intolerance; JSOG = Japan Society of Obstetrics and Gynecology; KQ = Key Question; NDDG = National Diabetes Data Group; NPV = negative predictive value; NICU = neonatal intensive care unit; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; PPV = positive predictive value; RCT = randomized controlled trial; wk(s) = week(s); WHO = World Health Organization

### Key Question 1

Fifty-one studies provided data for Key Question 1 that sought to examine the test characteristics and prevalence of current screening and diagnostic tests for gestational diabetes mellitus (GDM). The lack of a “gold standard” to confirm a diagnosis of GDM limits the ability to compare the results of studies that used different diagnostic criteria. Different criteria result in different rates of prevalence for GDM, regardless of similarities across study settings and patient characteristics.

The methodological quality of the studies was assessed using the QUADAS-2 tool. There were several concerns about the quality and applicability of the studies that addressed Key Question 1. First, there is concern about the risk for partial verification bias, which can occur when not all of the patients are verified by the reference standard. In 25 percent of the studies, women who were below the threshold for further screening on the oral glucose challenge test (OGCT) did not undergo an oral glucose tolerance test (OGTT) to confirm a diagnosis of GDM. For 35 percent of studies, it was unclear risk whether all patients underwent both tests. Another concern relates to the risk of diagnostic review bias in which the interpretation of the results of the reference standard may have been influenced by the knowledge of the results of the index test. Eighty percent of studies were assessed as high or unclear risk for this domain. A third concern relates to the domain of patient selection and the possibility of spectrum bias; 82 percent of studies were assessed as having high or unclear concerns for applicability. This was primarily because the studies were conducted in developing countries and used the World Health Organization (WHO) criteria to diagnose GDM.

The evidence showed that the 50 g OGCT with the 130 mg/dL cutpoint had higher sensitivity when compared with the 140 mg/dL cutpoint; however, specificity was lower (99 vs. 85 and 77 vs. 86, respectively). Both thresholds have high negative predictive values (NPV), but variable positive predictive values (PPV) across a range of GDM prevalence. When the risk of a missing a diagnosis is considered high, screening tests with high NPV are preferred at the expense of PPV. However, if the harm of an incorrect diagnostic is high, screening tests with high PPV are preferred at the expense of NPV. The Toronto Trihospital study found evidence to support the use of the lower screening cutpoint for higher risk patients, and the higher screening cutpoint for lower risk patients.15 While graded cutpoints for the diagnosis and treatment of dyslipidemia and osteoporosis based on risk factors are used in routine clinical practice, this approach is not widely accepted for the screening of GDM.

The large randomized controlled trials (RCTs) that showed some treatment benefits employed a two-step approach to screening and diagnosis for GDM.50,54 The practical efficiency of a two-step approach may be improved by setting a high threshold value on the screening test, above which no further confirmation testing is required for diagnosis. One study provides support for this approach by demonstrating that a threshold of 200 mg/dL on a 50 g OGCT resulted in 100 percent positive and negative predictive values for diagnosing GDM by Carpenter and Coustan (CC) and National Diabetes Data Group (NDDG) criteria.104

Only three studies included women who were in their first trimester of pregnancy and they used different diagnostic criteria. Therefore, no conclusions can be made about the test characteristics of screening tests for this group of women.

There are limited data to support the use of glycated hemoglobin (HbA1c) as a screening test. A study conducted in the United Arab Emirates using an HbA1c value of 5.5 percent or more lacked specificity (21 percent) despite good sensitivity (82 percent).113 A study conducted in Turkey showed that an HbA1c cutoff of 7.2 percent or more had 64 percent sensitivity and specificity.74 HbA1c does not perform as well as the 50 g OGCT as a screening test for GDM. However, when HbA1c is markedly elevated this supports a possible diagnosis of overt diabetes discovered in pregnancy. Since 2011-2012 the American Diabetes Association (ADA) has endorsed the use of an HbA1c of 6.5 percent or more as diagnostic of diabetes in nonpregnant women.36 Studies of HbA1c with trimester specific cutoffs to determine the value at which overt diabetes should be diagnosed in pregnancy are needed.

The sensitivity for fasting plasma glucose (FPG) of 85 mg/dL as a screening test for GDM is similar to that for the 50 OGCT with a threshold of 140 mg/dL; however, specificity is lower. As the threshold for fasting glucose is increased specificity is gained at the expense of sensitivity. The use of fasting glucose as a screening test for GDM has several clinical advantages over the OGCT when the tests are performed at or after 24 weeks' gestation. FPG has the advantage of greater reproducibility than post glucose load testing.165 In addition, it is easier to administer to women who cannot tolerate the glucose drink. Furthermore, fasting glucose has been positively associated with clinical outcomes of concern for GDM.142,166 However, a recent report from the Hyperglycemia and Adverse Pregnancy Outcome Study (HAPO) data found that a fasting glucose of 92 mg/dL did not diagnose GDM in women from Hong Kong and Bangkok as frequently as it did in other populations, and the elevated post glucose load glucose measurements were more frequently diagnostic of an International Association of the Diabetes in Pregnancy Study Groups (IADPSG) diagnosis of GDM in women from Hong Kong and Bangkok.6

Our review did not identify compelling evidence for or against risk factor-based screening. Naylor et al. used the Toronto Trihospital study data to develop a risk scoring system for GDM screening using variable glucose thresholds based on age, body mass index (BMI), and race. When applied to a validation group, sensitivity and specificity were similar to universal screening.167

There are limited data to draw conclusions about the effectiveness of the different options for diagnostic testing for GDM. Four studies compared the 75 g and 100 g load tests, but they were conducted in different countries and used different criteria or thresholds. However, because both the 75 g and 100 g load tests are positively linked with outcomes142,166 and the 75 g test is less time consuming, the adoption of the 75 g glucose load may be warranted even if thresholds continue to be debated3,142

The IADPSG has proposed the elimination of a screening test in favor of proceeding directly to a diagnostic test for GDM. We identified only one study124 that compared the IADPSG criteria with the Australasian Diabetes in Pregnancy Society (ADIPS) that used a two-step strategy. Sensitivity was 82 percent (95% CI, 74 to 88) and specificity was 94 percent (95% CI, 93 to 96).

#### Prevalence and Predictive Values

The prevalence of GDM varied across studies and the diagnostic criteria used. Factors contributing to the variability included differences in study setting (i.e., country), screening practices (e.g., universal vs. selective), and population characteristics (e.g., race/ethnicity, age, BMI).

The predictive value of a screening or diagnostic test is determined by the test's sensitivity and specificity and by the prevalence of GDM. Table 20 presents a series of scenarios that demonstrate the changes in PPV and NPV for three levels of prevalence (7 percent, 15 percent, and 25 percent).6 Separate tables are presented for different screening and diagnostic criteria. The higher the prevalence of GDM, the higher the PPV, or the more likely a positive result is able to predict the presence of GDM. When the prevalence of GDM is low, the PPV is also low, even when the test has high sensitivity and specificity. Generally the NPV (negative result rules out GDM) is very high—98 percent or better at a GDM prevalence of 7 percent.

Table 20 Relationship between predictive values and prevalence for different screening tests

Screening Test | Prevalence | Positive Predictive Value | Negative Predictive Value
50 g OGCT ≥140 mg/dL by CC/ADA (2000-2010) Sensitivity=85%; Specificity=86% | 7% | 31% | 99%
50 g OGCT ≥140 mg/dL by CC/ADA (2000-2010) Sensitivity=85%; Specificity=86% | 15% | 52% | 97%
50 g OGCT ≥140 mg/dL by CC/ADA (2000-2010) Sensitivity=85%; Specificity=86% | 25% | 67% | 95%
50 g OGCT ≥130 mg/dL by CC/ADA (2000-2010) Sensitivity=99%; Specificity=77% | 7% | 24% | 100%
50 g OGCT ≥130 mg/dL by CC/ADA (2000-2010) Sensitivity=99%; Specificity=77% | 15% | 43% | 100%
50 g OGCT ≥130 mg/dL by CC/ADA (2000-2010) Sensitivity=99%; Specificity=77% | 25% | 59% | 100%
50 g OGCT ≥140 mg/dL by NDDG Sensitivity=85%; Specificity=83% | 7% | 27% | 99%
50 g OGCT ≥140 mg/dL by NDDG Sensitivity=85%; Specificity=83% | 15% | 47% | 97%
50 g OGCT ≥140 mg/dL by NDDG Sensitivity=85%; Specificity=83% | 25% | 63% | 94%
50 g OGCT ≥130 mg/dL by NDDG Sensitivity = 88%; Specificity = 66% (median) | 7% | 16% | 99%
50 g OGCT ≥130 mg/dL by NDDG Sensitivity = 88%; Specificity = 66% (median) | 15% | 31% | 97%
50 g OGCT ≥130 mg/dL by NDDG Sensitivity = 88%; Specificity = 66% (median) | 25% | 46% | 94%
50 g OGCT ≥140 mg/dL by ADA 75 g Sensitivity=88%; Specificity=84% (median) | 7% | 29% | 99%
50 g OGCT ≥140 mg/dL by ADA 75 g Sensitivity=88%; Specificity=84% (median) | 15% | 49% | 98%
50 g OGCT ≥140 mg/dL by ADA 75 g Sensitivity=88%; Specificity=84% (median) | 25% | 65% | 95%
50 g OGCT ≥140 mg/dL by WHO Sensitivity=78%; Specificity=81% (median) | 7% | 24% | 98%
50 g OGCT ≥140 mg/dL by WHO Sensitivity=78%; Specificity=81% (median) | 15% | 42% | 95%
50 g OGCT ≥140 mg/dL by WHO Sensitivity=78%; Specificity=81% (median) | 25% | 58% | 92%
FPG (≥85 mg/dL) by CC/ADA (2000-2010) Sensitivity=87%; Specificity=52% | 7% | 12% | 98%
FPG (≥85 mg/dL) by CC/ADA (2000-2010) Sensitivity=87%; Specificity=52% | 15% | 24% | 96%
FPG (≥85 mg/dL) by CC/ADA (2000-2010) Sensitivity=87%; Specificity=52% | 25% | 38% | 92%
Risk factor screening by various criteria Sensitivity=84%; Specificity=72% (median) | 7% | 21% | 98%
Risk factor screening by various criteria Sensitivity=84%; Specificity=72% (median) | 15% | 38% | 96%
Risk factor screening by various criteria Sensitivity=84%; Specificity=72% (median) | 25% | 54% | 93%

TADA = American Diabetes Association; CC = Carpenter-Coustan; FPG = fasting plasma glucose; NDDG = National Diabetes Data Group; OGCT = oral glucose challenge test; WHO =World Health Organization

### Key Question 2

Only two retrospective cohort studies were relevant to Key Question 2 which asked about the direct benefits and harms of screening for GDM. One retrospective cohort study (n=1,000) conducted in Thailand showed a significantly greater incidence of cesarean deliveries in the screened group. A survey of a subset of participants (n=93) in a large prospective cohort study involving 116,678 nurses aged 25-42 years in the United States found the incidence of macrosomia (infant weight ≥ 4.3 kg) was the same in the screened and unscreened groups (7 percent each group).

There were no RCTs available to answer questions about screening. There is a paucity of evidence on the impact of screening women for GDM on health outcomes. The comparison for this question was women who had and had not undergone screening. Since screening is now commonplace it may be unlikely to identify studies or cohorts where this comparison is feasible.

### Key Question 3

Thirty-eight studies provided data for Key Question 3 that sought to examine health outcomes for women who meet various criteria for GDM and do not receive treatment. The majority of data came from cohort studies or the untreated groups from RCTs.

A wide variety of diagnostic criteria and thresholds were compared across the studies. The most common groups reported and compared were GDM diagnosed by CC criteria, no GDM by any criteria (normal), impaired glucose tolerance defined as one abnormal glucose value (OAV), and false positive (positive OGCT, negative OGTT).). Only single studies contributed data for many of the comparisons and outcomes, which does not allow for definitive conclusions. Further, results that showed no statistically significant differences cannot be interpreted as equivalence between groups nor do they rule out potential differences. A summary of the strength of evidence for key outcomes is provided in Table 21 and Table 22.

Table 21 Summary of strength of evidence for the association between different glucose levels and maternal outcomes (Key Question 3)

Outcome | | Number of Studies | Strength of Evidence | Summary
Preeclampsia | CC GDM vs. no GDM | 3 cohorts | Low | Statistically significant difference with fewer cases in the patient groups with no GDM (RR 1.50, 95% CI 1.07, 2.11)
Preeclampsia | CC GDM vs. false positive | 2 cohorts | Low | Statistically significant difference with fewer cases in the false-positive group (RR 1.51, 95% CI 1.17, 1.93)
Preeclampsia | NDDG false positive vs. no GDM | 2 cohorts | Insufficient | -
Preeclampsia | NDDG, 1 abnormal OGTT vs. no GDM | 1 cohort | Insufficient | -
Preeclampsia | WHO IGT vs. no GDM | 3 cohorts | Insufficient | -
Maternal weight gain | CC, 1 abnormal OGTT vs. no GDM | 1 cohort | Insufficient | -
Maternal weight gain | WHO IGT vs. no GDM | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IGT vs. no GDM | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IFG vs. no GDM | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IGT-2 vs.no GDM | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IGT IFG vs. no GDM | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IGT vs. IFG | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IGT vs. IGT-2 | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IGT vs. IGT IFG | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IFG vs. IGT-2 | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IFG vs. IGT IFG | 1 cohort | Insufficient | -
Maternal weight gain | IADPSG IGT-2 vs. IGT IFG | 1 cohort | Insufficient | -

CC = Carpenter-Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; IGT-2 = double impaired glucose tolerance; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test; RR = risk ratio; WHO = World Health Organization

Table 22 Summary of strength of evidence for the association between different glucose levels and neonatal/infant outcomes (Key Question 3)

Outcome | | Number of Studies | Strength of Evidence | Summary
Macrosomia >4,000 g | CC GDM vs. no GDM | 10 cohorts | Low | Statistically significant difference with fewer cases in the patient group with no GDM (RR 1.61, 95% CI 1.35, 1.92)
Macrosomia >4,000 g | CC GDM vs. false positive | 5 cohorts | Low | Statistically significant difference with fewer cases in the false-positive group (RR 1.36, 95% CI 1.10, 1.68)
Macrosomia >4,000 g | CC GDM vs. 1 abnormal OGTT | 3 cohorts | Low | No statistically significant difference (RR 0.99, 95% CI 0.92, 1.07)
Macrosomia >4,000 g | CC 1 abnormal OGTT vs. no GDM | 7 cohorts | Low | Statistically significant difference with fewer cases in the patient group with no GDM (RR 1.44, 95% CI 1.13, 1.82)
Macrosomia >4,000 g | CC false positive vs. no GDM | 5 cohorts | Low | No statistically significant difference (RR 1.02, 95% CI 0.85, 1.24)
Macrosomia >4,000 g | CC 1 abnormal OGTT vs. false positive | 3 cohorts | Insufficient | -
Macrosomia >4,000 g | NDDG GDM (unrecognized) vs. no GDM | 1 cohort | Insufficient | -
Macrosomia >4,000 g | NDDG false positive vs. no GDM | 4 cohorts | Low | Statistically significant difference with fewer cases in the patient group with no GDM (RR 1.44, 95% CI 1.10, 1.89)
Macrosomia >4,000 g | WHO GDM vs. no GDM | 1 cohort | Insufficient | -
Macrosomia >4,000 g | WHO IGT vs. no GDM | 1 cohort | Insufficient | -
Macrosomia >4,000 g | IADPSG GDM vs. no GDM | 2 cohorts | Insufficient | -
Macrosomia >4,500 g | CC GDM vs. no GDM | 3 cohorts | Low | Statistically significant difference with fewer cases in the patient group with no GDM (RR 2.52, 95% CI 1.65, 3.84)
Macrosomia >4,500 g | CC GDM vs. false positive | 2 cohorts | Insufficient | -
Macrosomia >4,500 g | CC false positive vs. no GDM | 2 cohorts | Insufficient | -
Macrosomia >4,500 g | NDDG GDM (unrecognized) vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | CC GDM vs. no GDM | 5 cohorts | Low | Statistically significant difference with fewer cases in the patient group with no GDM (RR 2.86, 95% CI 1.81, 4.51)
Shoulder Dystocia | CC GDM vs. false positive | 1 cohort | Insufficient | -
Shoulder Dystocia | CC 1 abnormal OGTT vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | CC 1 abnormal OGTT vs. false positive | 1 cohort | Insufficient | -
Shoulder Dystocia | NDDG GDM (unrecognized) vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | NDDG false positive vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | WHO IGT vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IGT vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IFG vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IGT-2 vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IGT IFG vs. no GDM | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IGT vs. IFG | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IGT vs. IGT-2 | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IGT vs. IGT IFG | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IFG vs. IGT-2 | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IFG vs. IGT IFG | 1 cohort | Insufficient | -
Shoulder Dystocia | IADPSG IGT-2 vs. IGT IFG | 1 cohort | Insufficient | -
Neonatal Hypoglycemia | CC GDM vs. no GDM | 3 cohorts | Insufficient | -
Neonatal Hypoglycemia | CC GDM vs. 1 abnormal OGTT | 1 cohort | Insufficient | -
Neonatal Hypoglycemia | CC 1 abnormal OGTT vs. no GDM | 4 cohorts | Insufficient | -
Neonatal Hypoglycemia | NDDG GDM vs. no GDM | 1 cohort | Insufficient | -
Neonatal Hypoglycemia | NDDG false positive vs. no GDM | 1 cohort | Insufficient | -
Neonatal Hypoglycemia | WHO IGT vs. no GDM | 3 cohorts | Insufficient | -

CC = Carpenter-Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; IGT-2 = double impaired glucose tolerance; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test; RR = risk ratio; WHO = World Health Organization

For maternal outcomes among the studies that compared groups as described above, women without GDM and those testing false positive showed fewer cases of preeclampsia than those meeting CC criteria; the strength of evidence was considered low for these two comparisons. No differences in preeclampsia were found for other comparisons, although evidence was based on few studies per comparison and strength of evidence was rated insufficient.

Fewer cases of cesarean section were found among women without GDM compared with women meeting criteria for CC GDM, CC, 1 abnormal OGTT, CC false positives, NDDG false positives, NDDG 1 abnormal oral glucose tolerance test, WHO IGT, IADPSG impaired fasting glucose (IFG), and IADPSG impaired glucose tolerance (IGT) IFG. There were fewer cases of cesarean section among false positives compared with women meeting criteria for CC GDM. For 12 other comparisons, there were no differences in rates of cesarean delivery.

For maternal hypertension, significant differences were found for eight of 16 comparisons; many comparisons were based on single studies. No GDM groups showed lower incidence of maternal hypertension when compared with CC GDM, CC, 1 abnormal OGTT, IADPSG IFG, IADPSG double impaired glucose tolerance (IGT-2), and IADPSG IGT IFG. Other comparisons showing significant differences were CC GDM versus false positives (lower incidence for false positives), IADPSG IGT versus IGT IFG (lower incidence for IGT), and IADPSG IFG versus IGT IFG (lower incidence for IFG).

Based on single studies, no differences were observed for maternal birth trauma for three comparisons. For maternal weight gain (less weight gain considered beneficial), significant differences were found for three of 12 comparisons: IADPSG IGT versus no GDM (favored IGT), IADPSG IFG versus no GDM (favored IFG), IADPSG IGT-2 versus no GDM (favored IGT-2). All comparisons were based on single studies and the strength of evidence was insufficient. For maternal mortality/morbidity, single studies contributed to three comparisons and no differences were found except for fewer cases among patient groups with no GDM compared with IADPSG GDM. No studies provided data on long-term maternal outcomes, such as type 2 diabetes mellitus, obesity and hypertension.

The most commonly reported outcome for the offspring was macrosomia >4,000 g. Six of 11 comparisons showed a significant difference: there were fewer cases in the group without GDM compared with CC GDM, CC 1 abnormal OGTT, NDDG GDM (unrecognized), NDDG false positives, and WHO IGT. Fewer cases were found for women with false-positive results compared with CC GDM. The strength of evidence for these findings was low to insufficient. Data for macrosomia >4,500 g was available for four comparisons and showed significant differences in two cases: patient groups with no GDM had fewer cases compared with women with CC GDM and with unrecognized NDDG GDM. The strength of evidence was low and insufficient, respectively.

For shoulder dystocia, significant differences were found for seven of 17 comparisons; all but one comparison was based on single studies (insufficient strength of evidence). Patient groups with no GDM showed lower incidence of shoulder dystocia when compared with CC GDM (5 studies; low strength of evidence), NDDG GDM (unrecognized), NDDG false positive, WHO IGT, IADPSG IFG, and IADPSG IGT IFG. The other significant difference showed lower incidence among the false-positive group compared with CC 1 abnormal OGTT. For fetal birth trauma or injury, four studies compared CC GDM, NDDG GDM and WHO IGT with patient groups without GDM (insufficient strength of evidence). No differences were observed except for NDDG GDM which favored the group with no GDM.

Only one difference was found for neonatal hypoglycemia with fewer cases among patient groups without GDM compared with those meeting CC criteria; strength of evidence was insufficient. There were 16 comparisons for hyperbilirubinemia; the majority were based on single studies. Three comparisons showed significant differences between groups: patient groups with no GDM had fewer cases compared with CC false positive, IADPSG IGT, and IADPSG IGT-2, respectively. No differences were found for fetal morbidity/mortality for any of eight comparisons which may be attributable to small numbers of events within some comparisons. Moreover, comparisons were based on single studies.

Based on a single study, significant differences were found in prevalence of childhood obesity for CC GDM versus no GDM (lower prevalence for no GDM) and CC GDM versus false positives (lower prevalence for false positives). This was consistent for both childhood obesity >85^th^ percentile as well as >95^th^ percentile. However, this study was unable to control for maternal weight or BMI which are established predictors of childhood obesity. No differences, based on the same single study, were found for the other four comparisons within >85^th^ or >95^th^ percentiles. No other studies provided data on long-term outcomes, including type 2 diabetes mellitus and transgenerational GDM.

In summary, different thresholds of glucose intolerance impact maternal and neonatal outcomes of varying clinical importance. While many studies have attempted to measure the association between various criteria for GDM and pregnancy outcomes in the absence of treatment, the ability of a study or pooled analysis to find a statistically significant difference in pregnancy outcomes appears more dependent on study design, in particular the size of the study or pooled analysis, rather than the criteria used for diagnosing GDM. This is not surprising given the strong support found for a continuous positive relationship between glucose and a variety of pregnancy outcomes. Moreover, two methodologically strong studies met the inclusion criteria for this question but could not be pooled with the other studies because they examined glucose thresholds as a continuous outcome.3,91 These studies demonstrated a continuous positive relationship between increasing glucose levels and the incidence of primary cesarean section, and macrosomia. One of these studies also found significantly fewer cases of preeclampsia, cesarean section, shoulder dystocia and/or birth injury, clinical neonatal hypoglycemia, and hyperbilirubinemia for women with no GDM compared with those meeting IADPSG criteria.3 The clinical significance of absolute differences in event rates requires contemplation by decision makers even though statistical significance was reached at the strictest diagnostic glucose thresholds for some outcomes.

This question focused on outcomes for women who did not receive treatment for GDM. While women with untreated GDM have a variety of poorer outcomes than women without GDM, it cannot be assumed that treatment of GDM reverses all the short- and long-term poor outcomes observed in women with untreated GDM. Some of the reasons for the poorer outcomes in women that have untreated GDM may not be modifiable, such as the influences of genetic makeup. The strength of evidence was insufficient for most outcomes and comparisons in this question due to high risk of bias (observational studies), inconsistency across studies, and/or imprecise results.

### Key Question 4

Eleven studies provided data for Key Question 4 to assess the impact of treatment for GDM on health outcomes of mothers and offspring. All studies compared diet modification, glucose monitoring, and insulin as needed with standard care. The strength of evidence for key outcomes is summarized in Table 23.

Table 23 Summary of strength of evidence for benefits of treatment (Key Question 4)

| Outcome | Number of Studies | Strength of Evidence | Summary
Maternal outcomes | Preeclampsia | 3 RCTs, 1 cohort | Moderate | Significant difference in favor of treatment for RCTs (RR 0.62, 95% CI 0.43, 0.89). No difference observed for cohort study.
Maternal outcomes | Maternal weight gain | 4 RCTs, 2 cohorts | Insufficient | Results not pooled for RCTs due to substantial heterogeneity. No difference for cohort studies (MD -1.04, 95% CI -2.89, 0.81).
Infant outcomes | Birth injury | 2 RCTs, 1 cohort | Insufficient | No difference for RCTs (RR 0.48, 95% CI 0.12, 1.90). Significant difference favoring treatment for cohort study (RR 0.02, 95% CI 0.00, 0.22).
Infant outcomes | Shoulder dystocia | 3 RCTs, 4 cohorts | Moderate | Significant difference in favor of treatment for RCTs (RR 0.42, 95% CI 0.23, 0.77) and cohort studies (RR 0.38, 95% CI 0.19, 0.78).
Infant outcomes | Neonatal hypoglycemia | 4 RCTs, 2 cohorts | Low | No difference for RCTs (RR 1.18, 95% CI 0.92, 1.52) or cohort studies (RR 0.55, 95% CI 0.10, 2.97).
Infant outcomes | Macrosomia (>4,000 g) | 5 RCTs, 6 cohorts | Moderate | Significant difference in favor of treatment for RCTs (RR 0.50, 95% CI 0.35, 0.71). Results not pooled for cohort studies due to substantial heterogeneity.
Long-term metabolic outcomes in offspring | Impaired glucose tolerance | 1 RCT | Insufficient | No difference between groups (RR 5.63, 95% CI 0.31, 101.32).
Long-term metabolic outcomes in offspring | Type 2 diabetes mellitus | 1 RCT | Insufficient | No difference between groups (RR 1.88, 95% CI 0.08, 44.76).
Long-term metabolic outcomes in offspring | BMI | 2 RCTs | Low | No difference between groups (RR 1.26, 95% CI 0.86, 1.84)

BMI = body mass index; CI = confidence interval; MD = mean difference; RCT = randomized controlled trial; RR = risk ratio

There was moderate evidence showing a significant difference for preeclampsia with fewer cases in the treated group. There was inconsistency across studies in terms of differences in maternal weight gain and the strength of evidence was considered insufficient. There were no data on long-term outcomes among women including type 2 diabetes mellitus, obesity, and hypertension.

In terms of infant outcomes, there was insufficient evidence to make a conclusion for birth injury. This was driven by lack of precision in the effect estimates and inconsistency across studies: there was no difference for RCTs but a significant difference favoring treatment in the one cohort study. The incidence of shoulder dystocia was significantly lower in the treated groups, and this finding was consistent for the 3 RCTs and 4 cohort studies. Overall, the evidence for shoulder dystocia was considered moderate showing a difference in favor of the treated group. For neonatal hypoglycemia, the strength of evidence was low suggesting no difference between groups. There was moderate evidence showing significantly lower incidence of macrosomia among the treated groups.

Only one study provided data on long-term metabolic outcomes among the offspring at 7 to 11 year followup. The strength of evidence was insufficient to reach a conclusion. For both outcomes—impaired glucose tolerance and type 2 diabetes mellitus—no differences were found between groups although the estimates were imprecise. No differences were observed in single studies that assessed BMI >95 (7-11 year followup) and BMI >85 percentile (5-7 year followup). Overall, pooled results showed no difference in offspring BMI and the strength of evidence was considered low.

In summary, there was moderate evidence showing differences in preeclampsia and shoulder dystocia with fewer cases among women (and offspring) who were treated compared with those not receiving treatment. There was also moderate evidence showing significantly fewer cases of macrosomia (>4,000 g) among offspring of women who received treatment for GDM. The results were driven by the two largest RCTs, the Maternal Fetal Medicine Unit (MFMU)54 and the Australian Carbohydrate Intolerance in Pregnancy Study (ACHOIS),50 which had unclear and low risk of bias, respectively. There was little evidence showing differences in other key maternal and infant outcomes between groups. One potential explanation is that for the most part the study populations included women whose glucose intolerance was less marked, as those whose glucose intolerance was more pronounced would not have been entered into a trial where they may be assigned to a group receiving no treatment. For outcomes where results were inconsistent between studies, different study glucose threshold entry criteria did not explain the variation. For some outcomes, particularly the long-term outcomes, the strength of evidence was insufficient or low suggesting that further research may change the results and increase our confidence in the results. Moreover, for some outcomes events were rare and the studies may not have had the power to detect clinically important differences between groups; therefore, findings of no significant difference should not be interpreted as equivalence between groups.

### Key Question 5

Five studies provided data for Key Question 5 on the harms associated with treatment of GDM. There was no evidence for some of the outcomes stipulated in the protocol including costs and resource allocation.

Four of the studies provided data on the incidence of infants that were small for gestational age and showed no significant difference between groups. This finding may have resulted from inadequate power to detect differences due to a small number of events; therefore, the finding of no significant difference should not be interpreted as equivalence between groups. Four studies provided data on admission to the neonatal intensive care unit (NICU) and showed no significant differences overall. One study was an outlier as it showed significantly fewer NICU admissions in the group receiving no treatment. This difference may be attributable to site-specific policies and procedures. Two studies reported on the number of prenatal visits and generally found significantly more visits among the treatment groups.

Two RCTs showed no significant difference overall in the rate of induction of labor, although there was important statistical heterogeneity between studies. One RCT showed significantly more inductions of labor in the treatment group50 while the other study did not.54 Different study protocols may account for the heterogeneity of results between studies. In the first study, that showed more inductions of labor in the treatment group, no recommendations were provided regarding obstetrical care. In the later study, antenatal surveillance was reserved for standard obstetrical indications. Based on the studies included in Key Question 4, there was no difference in Cesarean section between treatment and non treatment GDM (5 RCTs and 6 cohort studies).

A single study assessed depression and anxiety at 6 weeks after study entry and 3 months postpartum using the Spielberger State-Trait Anxiety Inventory and the Edinburgh Postnatal Depression Score, respectively. There was no significant difference between groups in anxiety at either time point, although there were significantly lower rates of depression in the treatment group at 3 months postpartum. These results should be interpreted cautiously because the assessment of depression and anxiety was conducted in a subgroup of the larger RCT. Maternal stress in pregnancy has been associated with poor metabolic consequences in offspring.168 Other research found that women with GDM compared with glucose tolerant women had a higher level of anxiety at time of the first assessment; however, before delivery these differences in anxiety scores did not persist.169

## Findings in Relationship to What Is Already Known

This review provides evidence that treating GDM reduces some poor maternal and neonatal outcomes. The recent randomized trial published in 2009 by the MFMU54 reinforces the findings of the earlier ACHOIS trial which was published in 2005 50 and included in an earlier version of this review.53 Both trials showed that treating GDM to targets of 5.3 or 5.5 mmol/L fasting and 6.7 or 7.0 mmol/L 2 hours post-meal reduced neonatal birthweight, large for gestational age, macrosomia, shoulder dystocia, and preeclampsia without a reduction in neonatal hypoglycemia or hyperbilirubinemia/jaundice requiring phototherapy, or an increase in small for gestational age. In contrast to the ACHOIS trial, MFMU demonstrated a reduced cesarean section rate in the GDM treatment group. The failure of ACHOIS to find a lower cesarean section rate despite reduced neonatal birthweight and macrosomia may have been the result of differing obstetrical practices or the different populations studied (e.g., the inclusion of some women with more marked glucose intolerance in ACHOIS as reflected by the increased prevalence of insulin use; more black and Hispanic women in the MFMU study). Differences may have also resulted due to study design: in ACHOIS, participants did not receive specific recommendations regarding obstetrical care, thus replicating obstetrical care for women with GDM. In the MFMU study, antenatal surveillance was reserved for standard obstetrical indications. Our findings of the effect of treatment of GDM is similar to a systematic review and meta-analysis published in 2010 by Horvath et al.170 that included two older RCTs of GDM that were not included in our analysis because we restricted our inclusion criteria to studies published after 1995.

The Hyperglycemia and Adverse Pregnancy Outcomes (HAPO) Study Cooperative Research Group 3 confirmed findings of the earlier Toronto Trihospital study 142 in a large international sample of women with a simpler 75 g OGTT showing a continuous positive association between maternal glucose and increased birthweight, as well as fetal hyperinsulinemia (HAPO only), at levels below diagnostic thresholds for GDM that existed at the time of the study. However, no clear glucose thresholds were found for fetal overgrowth or a variety of other maternal and neonatal outcomes. Subsequently, the IADPSG developed diagnostic thresholds for GDM based on a consensus of expert opinion of what was considered to be the most important outcomes and the degree of acceptable risk for these outcomes. The thresholds chosen by the IADPSG were derived from the HAPO data to identify women with a higher risk (adjusted odds ratio 1.75) of large for gestational age, elevated c-peptide, high neonatal body fat compared with the mean maternal glucose values of the HAPO study. The glucose threshold chosen by the IADPSG represents differing levels of risk for other outcomes. Specifically the IADPSG thresholds represent a 1.4 (1.26-1.56) risk for pregnancy induced hypertension and a 1.3 (1.07,1.58) risk for shoulder dystocia.

Neither recent RCT was designed to determine diagnostic thresholds for GDM or therapeutic glucose targets. However, it is noteworthy that therapeutic glucose targets for both ACHOIS and MFMU were above the proposed diagnostic criteria of the IADPSG (fasting 5.5 mmol/L (99 mg/dL) and 5.3 mmol/L (95 mg/dL and 2 hour post-meal of 7.0 mmol/L (126 mg/dL and 6.7 mmol/L 120 mg/dL), respectively). A change in diagnostic criteria without addressing management thresholds could contribute to clinical confusion. If diagnostic thresholds for GDM below the treatment targets of the large RCTs are endorsed, this could ethically obstruct the possibility of future RCTs to compare different treatment targets above such diagnostic thresholds.

It has been hypothesized that treatment of GDM may reduce future poor metabolic outcomes for children born to mothers with GDM. If true, the potential for long-term gain is important from a clinical and public health perspective and may justify the “costs” of screening and treating women for GDM. However, the followup of offspring from two RCTs 50,96 and a HAPO cohort in Belfast 171 currently fail to support this hypothesis. This may be explained in part due to insufficient length of followup or inadequate numbers of events.

The HAPO study showed that maternal weight and glucose predict large for gestational age. However, body mass index was the better predictor of large for gestational age than glucose until glucose thresholds higher than the diagnostic thresholds set by the IADPSG were reached.172,173 Most cases of large for gestational age occur in neonates of mothers with normal glycemia. A large observational study found that the upper quartile of maternal BMI accounted for 23 percent of macrosomia, while GDM was responsible for only 3.8 percent.174 The ongoing obesity epidemic in the United States warrants careful consideration of a diagnostic approach for GDM that incorporates maternal BMI. This would require the development and validation of a risk model that incorporates maternal BMI as well as other modifiable risk factors. Such a model could facilitate the identification of women at high risk of adverse pregnancy outcomes and minimize exposure of lower risk women to unnecessary interventions.

## Applicability

There are several issues that may limit the applicability of the evidence presented in this review to the U.S. population, and these vary slightly by Key Question. All of the Key Questions asked about the effects of screening and treatment before and after 24 weeks' gestation. The vast majority of included studies screened women after 24 weeks' gestation, therefore the results are not applicable to screening and treatment earlier in gestation.

For Key Question 1 on the test properties of screening and diagnostic tests, comparisons involving the WHO criteria are less applicable to the U.S. setting as these criteria are not used in North America. There were insufficient data from the included studies to assess the performance of screening or diagnostic tests for specific patient characteristics (e.g., BMI, race/ethnicity). Therefore it is unclear whether the evidence applies to specific subpopulations of women.

For Key Question 2, limited evidence was identified because the comparison of interest was women who had not undergone screening. As screening is routine in prenatal care in the United States, the evidence (or limited evidence) is likely not helpful for U.S. decisionmaking and a refinement of this question may be appropriate to reflect current practices and outstanding questions.

With respect to Key Question 3, all studies or groups included for analysis involved women who had not received treatment for GDM. It cannot be assumed that the same association and outcomes would be observed in clinical practice where standard care is to screen for and treat GDM. The untreated women may differ from the general population in ways that are related to the reasons for which they did not seek or receive early prenatal care (e.g., socioeconomic status). That is, the reasons that they did not receive treatment for GDM are varied; some reasons such as late presentation for obstetrical care may confound the observed association with health outcomes. Attempts were made to control for these factors in some studies by including a group of women without GDM with similar known confounders146 or by adjusting for known confounders in the analysis. The adjusted estimates did not change the overall pooled results in the majority of cases and did not change the overall conclusions.

The majority of the studies for Key Questions 4 and 5 pertaining to the benefits and harms of treatment for GDM were conducted in North America or Australia. Most of the North American studies were inclusive of mixed racial populations and are likely applicable to the general U.S. population. Even though the Australian RCT50 population had more white women with a lower BMI than the U.S. RCT (MFMU54), this should not affect applicability of most of their findings because these patient characteristics would be factors associated with lower risk of poor outcomes. Differences in physician or hospital billing structures between the United States and Australia may have accounted for the discrepant findings with respect to NICU admissions and as a result limit the applicability of this finding in the United States. Among the studies included in Key Questions 4 and 5, a variety of glucose threshold criteria were used for inclusion, varying from 50 g screen positive with nondiagnostic oral glucose tolerance tests to women who met National Diabetes Data Group criteria for a diagnosis of GDM. The two large RCTs used different glucose thresholds for entry in their trials: WHO and CC criteria with a fasting glucose <95 mg/dL (5.3 mmol/L), respectively.50,54 The mean glucose levels at study entry were similar between these two RCTs, which may reflect a reluctance to assign women with more marked glucose intolerance to a group receiving no treatment. The results may not be applicable to women with higher levels of glucose intolerance.

## Limitations of the Evidence Base

There is sparse evidence to clarify issues regarding the timing of screening and treatment for GDM (i.e., before and after 24 weeks' gestation). Earlier screening will help identify overt type 2 diabetes mellitus and distinguish this from GDM. This has important implications for clinical management and ongoing followup beyond pregnancy. Previously unrecognized type 2 diabetes mellitus diagnosed in pregnancy should be excluded from the diagnosis of GDM because this condition has the highest perinatal mortality rate of all classes of glucose intolerance in pregnancy.175 This distinction within research studies will provide more targeted evidence to assist obstetrical care providers to risk stratify obstetrical care and glycemic management of patients with overt type 2 diabetes mellitus diagnosed in pregnancy and those with less pronounced pregnancy-induced glucose intolerance. This will also facilitate better comparability across future studies. There were few data available on long-term outcomes. Furthermore, the studies included in this review do not provide evidence of a direct link between short-term and long-term outcomes (e.g., macrosomia and childhood obesity).

Care provider knowledge of the glucose screening and diagnostic results may have introduced a bias if their subsequent treatment of women differed depending on the results. This was of particular concern for Key Question 3. For Key Question 3, which assessed how the various criteria for GDM influenced pregnancy outcomes, many of the statistically significant differences seemed to be driven by the size of the study or pooled analysis, i.e., statistically significant differences could be found if the sample were sufficiently large. However, these differences may not be clinically important. The absolute differences in event rates between different glucose thresholds need careful consideration by decisionmakers even though statistically significant differences were found. Another key limitation with the evidence for Key Question 3 is that the studies included were cohort studies, many of which did not control for potential confounders. Therefore, any associations between glucose thresholds and outcomes should be interpreted with caution.

Given that the large landmark studies91,142 show a continuous relationship between glucose and maternal and neonatal outcomes, the lack of clear thresholds contributes to the uncertainty regarding a diagnostic threshold for GDM. While there is controversy about where to set lower limits for diagnostic criteria, the identification of overt diabetes in pregnancy is imperative if this diagnosis has not occurred prior to pregnancy. Overt diabetes first identified in pregnancy should be distinguished from GDM in order to gain a better understanding of the true risk of GDM to pregnancy outcomes. Unfortunately there is no literature to guide diagnostic criteria for a diagnosis of overt diabetes in pregnancy.

There were several methodological concerns for this evidence base. For example, risk of spectrum bias and partial verification bias (Key Question 1); different definitions or methods of assessing key outcomes (e.g., clinical vs. biochemical neonatal hypoglycemia and hyperbilirubinemia) (Key Questions 3 and 4); and, lack of blinding of treatment arms in some studies (Key Questions 4 and 5).

## Future Research

Several important gaps in the current literature exist:

- The adoption of a consistent comparator for diagnosis of GDM, such as the 75 g OGTT, would facilitate comparisons across studies even if different diagnostic thresholds are used.
- Further analysis of the HAPO data could help answer some outstanding questions. For example, further analysis could better define absolute differences in rare event rates. This evidence could be used to inform discussions about the clinical importance of absolute differences in event rates at thresholds other than those of the IADPSG. Such analyses should include adjustment for important confounders such as maternal BMI.
- Further analysis of the HAPO data examining center to center differences in glucose outcome relationships would be helpful in determining the usefulness of FPG as a screening test for GDM.
- Research is needed to clarify issues regarding earlier screening and treatment, particularly as they relate to the diagnosis, treatment, and long-term outcomes of pregestational (overt) diabetes.
- FPG is a screening test that requires further research, given that the reproducibility of fasting glucose measurement is superior to post glucose load measurements.165
- Further study of the long-term metabolic impact on offspring whose mothers have been treated for GDM is warranted. In addition, data on the influences of GDM treatment on long-term breastfeeding success have not been studied. The association of breastfeeding with reduced poor metabolic outcomes in offspring of GDM has been found to have a dose dependent response with duration of breastfeeding.176
- Well-conducted prospective cohort studies of the “real world” impact of GDM treatment on care utilization are needed.
- Research is needed to help determine the glucose thresholds and treatment targets at which GDM treatment benefits outweigh the risks of treatment and no treatment. This will best be achieved through well-conducted, large RCTs that randomize women with GDM to different glucose treatment targets.
- While this review did not identify evidence of substantial harms to treatment, the populations considered were mostly women whose GDM was controlled without medication. There is a risk for more precautionary management of women diagnosed with GDM who are perceived by clinicians to be at greater risk, such as those managed with insulin, which may result in unnecessary interventions (e.g., cesarean section).177 Therefore, RCTs investigating the care of women diagnosed with GDM, including fetal surveillance protocols, are needed to guide obstetrical investigations and management of GDM. Further, RCTs comparing delivery management for GDM with and without insulin or medical management are needed to provide clinicians guidance on appropriate timing and management of delivery in women with GDM to avoid unnecessary intervention in “the real world” driven by health care provider apprehension.
- Long-term studies that evaluate the potential increased or decreased resource utilization associated with the implementation of diabetes prevention strategies after a diagnosis of GDM are required.
- Studies to assess the long-term impact that a label of GDM may have for future pregnancy planning, future pregnancy management, and future insurability are required.
- The increased prevalence of type 2 diabetes mellitus in women of reproductive age merits consideration of preconception screening for overt diabetes in women at risk of type 2 diabetes. In addition to poor maternal and neonatal outcomes associated with overt diabetes in pregnancy, there is potential for benefit of preconception care.
- Long-term benefits and harms need to be evaluated among different treatment modalities for GDM (e.g., diet, exercise, insulin, oral glucose lowering medications, and/or combinations of these).
- Since 2011-2012 the ADA has endorsed the use of an HbA1c of 6.5 percent or more as diagnostic of diabetes in nonpregnant women.36 Studies of HbA1c with trimester-specific cutoffs to determine the value at which overt diabetes should be diagnosed in pregnancy are needed.

## Limitations of the Review

This review followed rigorous methodological standards which were detailed a priori. The limitations of the review to fully answer the Key Questions are largely due to the nature and limitations of the existing evidence.

There are several limitations that need to be discussed regarding systematic reviews in general. First, there is a possibility of publication bias. The impact of publication bias on the results of diagnostic test accuracy reviews (Key Question 1) is not well understood nor have the tools to investigate publication bias in these reviews been developed. For the remaining Key Questions we may be missing unpublished and/or negative therapy studies, and may be overestimating the benefits of certain approaches. However, we conducted a comprehensive and systematic search of the published literature for potentially relevant studies. Search strategies included combinations of subject headings and free text words. These searches were supplemented by handsearching for gray literature (i.e., unpublished or difficult to find studies). Despite these efforts, we recognize that we may have missed some studies.

There is also a possibility of study selection bias. However, we employed at least two independent reviewers and feel confident that the studies that were excluded from this report were done so for consistent and appropriate reasons. Our search was comprehensive, so it is unlikely that there are many studies in press or publication that were missed.

Cost analysis of different screening and diagnostic approaches was not addressed in this review.

## Conclusions

There was limited evidence regarding the test characteristics of current screening and diagnostic strategies for GDM. Lack of an agreed upon gold standard for diagnosis of GDM creates challenges for assessing the accuracy of tests and comparing across studies. The 50 g OGCT with a glucose threshold of 130 mg/dL versus 140 mg/dL improves sensitivity and reduces specificity (10 studies). Both thresholds have high NPV, but variable PPV across a range of GDM prevalence. There was limited evidence for the screening of GDM diagnosed less than 24 weeks' gestation (3 studies). Single studies compared the diagnostic characteristics of different pairs of diagnostic criteria in the same population. The use of fasting glucose (≥85 mg/dL) as a screen for GDM may be a practical alternative because of similar test characteristics to the OGCT particularly in women who cannot tolerate any form of oral glucose load.

Evidence supports benefits of treating GDM with little evidence of short-term harm. Specifically, treatment of GDM results in lower incidence of preeclampsia, macrosomia, and large for gestational age infants. Current research does not demonstrate a treatment effect of GDM on clinical neonatal hypoglycemia or future poor metabolic outcomes of the offspring. RCTs of GDM treatment show limited harm related to treating GDM, other than an increased demand for services. There is a risk for more precautionary management of women diagnosed with GDM who are perceived by clinicians to be at greater risk, such as those managed with insulin, which may result in unnecessary interventions (e.g., cesarean section); however, this review found limited data for these outcomes and further research on the care of women diagnosed with GDM (e.g., fetal surveillance protocols) is warranted.

What remains less clear is what the lower limit diagnostic thresholds for GDM should be. Given the continuous association between glucose and a variety of outcomes, decisions should be made in light of what outcomes that are altered by treatment are most important and what level of increased risk is acceptable. A dichotomous view of GDM may no longer be appropriate, given evidence of a continuous relationship between maternal blood glucose and pregnancy outcomes. An alternative approach would be to define different glucose thresholds based on maternal risk for poor pregnancy outcomes.

Further study is needed regarding the long-term metabolic impact on offspring of mothers receiving GDM treatment; the “real world” impact of GDM treatment on care utilization outside of structured research trials; and, the impact of the timing of screening for GDM, particularly before 24 weeks' gestation and in the first trimester of pregnancy. Early screening could help identify pregestational (i.e., overt) diabetes. Research is urgently required to determine the best way to diagnose and manage overt diabetes in pregnancy, particularly in an era of increasing rates of obesity and diabetes in the U.S. population.