# Adjusted Analyses for KQ3

Tables G-1 and G-2, on the following pages, provide unadjusted and adjusted results for maternal and offspring outcomes, respectively. The data that contributed to the meta-analysis for each comparison and outcome are provided. The data used in the meta-analyses and reported in the main report were unadjusted data from the relevant studies. We have also included the following for each study: whether the study provided adjusted results; what the adjusted effect estimate was (with its 95% confidence interval); whether the adjusted results were different from the unadjusted results in terms of statistical significance; and the variables that were controlled for in the adjusted analyses. For the overall pooled estimate within each comparison, we have noted whether the estimate would have changed if the adjusted values were used rather than the unadjusted values. For comparisons and outcomes with single studies, we have indicated whether the unadjusted and adjusted estimates differed in terms of statistical significance

Table G-1 Maternal outcomes: Unadjusted data included in meta-analyses for Key Question 3 and adjusted effect estimates where available from included studies

Table G-2 Offspring outcomes: Unadjusted data included in meta-analyses for Key Question 3 and adjusted effect estimates where available from included studies