# List of Excluded Studies and Unobtained Studies

## Excluded – Comparator (N=227)

1 Catalano PM, Avallone DA, Drago NM, et al. Reproducibility of the oral glucose tolerance test in pregnant women. Am J Obstet Gynecol. 1993;169(4):874-81. [pmid: 8238142].
2 Schrader HM, Jovanovic-Peterson L, Bevier WC, et al. Fasting plasma glucose and glycosylated plasma protein at 24 to 28 weeks of gestation predict macrosomia in the general obstetric population. Am J Perinatol. 1995;12(4):247-51. [pmid: 7575827].
3 Moses RG, Griffiths RD. Can a diagnosis of gestational diabetes be an advantage to the outcome of pregnancy?. J Soc Gynecol Investig. 1995;2(3):523-5.
4 Bassaw B, Ataullah I, Roopnarinesingh S, et al. Diabetes in pregnancy. Int J Gynaecol Obstet. 1995;50(1):5-9. [pmid: 7556860].
5 de VM, Major CA, Morgan MA, et al. Postprandial versus preprandial blood glucose monitoring in women with gestational diabetes mellitus requiring insulin therapy. N Engl J Med. 1995;333(19):1237-41. [pmid: 7565999].
6 Damm P, Kuhl C, Hornnes P, et al. A longitudinal study of plasma insulin and glucagon in women with previous gestational diabetes. Diabetes Care. 1995;18(5):654-65. [pmid: 8586003].
7 Koukkou E, Taub N, Jackson P, et al. Difference in prevalence of gestational diabetes and perinatal outcome in an innercity multiethnic London population. Eur J Obstet Gynecol Reprod Biol. 1995;59(2):153-7. [pmid: 7657009].
8 Gribble RK, Meier PR, Berg RL. Blood glucose limits in the diagnosis of impaired glucose tolerance during pregnancy. Relation to morbidity. Obstet Gynecol. 1995;86(3):405-10. [pmid: 7651652].
9 al-Najashi SS. Control of gestational diabetes. Int J Gynaecol Obstet. 1995;49(2):131-5. [pmid: 7649316].
10 Kjos SL, Peters RK, Xiang A, et al. Predicting future diabetes in Latino women with gestational diabetes. Utility of early postpartum glucose tolerance testing. Diabetes. 1995;44(5):586-91. [pmid: 7729620].
11 Reece EA, Hagay Z, Gay LJ, et al. A randomized clinical trial of a fiber-enriched diabetic diet vs. the standard American Diabetes Association-recommended diet in the management of diabetes mellitus in pregnancy. J Matern Fetal Invest. 1995;5(1):8-12.
12 Hughes PF, Agarwal M, Newman P, et al. An evaluation of fructosamine estimation in screening for gestational diabetes mellitus. Diabet Med. 1995;12(8):708-12. [pmid: 7587011].
13 Agardh CD, Aberg A, Norden NE. Glucose levels and insulin secretion during a 75 g glucose challenge test in normal pregnancy. J Intern Med. 1996;240(5):303-9. [pmid: 8946813].
14 Hod M, Rabinerson D, Kaplan B, et al. Perinatal complications following gestational diabetes mellitus how ‘sweet’ is ill?. Acta Obstet Gynecol Scand. 1996;75(9):809-15. [pmid: 8931504].
15 Nasrat HA, Ardawi MS, Abalkhail BA. The diagnosis of “pathological hyperglycaemia' in gestational diabetes in a high risk obstetric population. Diabetic Med. 1996;13(10):861-7. [pmid: 8911779].
16 Di SN, Ronsisvalle E, Fulghesu AM, et al. Insulin plasma levels in pregnant patients with impaired glucose tolerance: relationship with pregnancy outcome. Gynecol Obstet Invest. 1996;42(1):16-20. [pmid: 8840171].
17 Tranquilli AL, Pizzichini L, Cingolani F, et al. Prediction of the need for insulin therapy in pregnant women with impaired gestational glucose tolerance (IGGT). Clin Exp Obstet Gynecol. 1996;23(2):79-82. [pmid: 8737618].
18 Moses RG. The recurrence rate of gestational diabetes in subsequent pregnancies. Diabetes Care. 1996;19(12):1348-50. [pmid: 8941462].
19 Di CG, Benzi L, Casadidio I, et al. Screening of gestational diabetes in Tuscany: results in 2000 cases. Ann Ist Super Sanita. 1997;33(3):389-91. [pmid: 9542268].
20 Fedele D, Lapolla A. A protocol of screening of gestational diabetes mellitus. Ann Ist Super Sanita. 1997;33(3):383-7. [pmid: 9542267].
21 Bienstock JL, Blakemore KJ, Wang E, et al. Managed care does not lower costs but may result in poorer outcomes for patients with gestational diabetes. Am J Obstet Gynecol. 1997;177(5):1035-7. [pmid: 9396888].
22 Helton MR, Arndt J, Kebede M, et al. Do low-risk prenatal patients really need a screening glucose challenge test?. J Fam Pract. 1997;44(6):556-61. [pmid: 9191628].
23 Avery MD, Leon AS, Kopher RA. Effects of a partially home-based exercise program for women with gestational diabetes. Obstet Gynecol. 1997;89(1):10-5. [pmid: 8990428].
24 al-Najashi SS. Diagnosis of gestational diabetes mellitus. A study of 315 pregnant women at King Fahd Hospital of the University, Al-Khobar, Saudi Arabia. Bahrain Med Bull. 1997;19(4):104-7.
25 Persson B, Edwall L, Hanson U, et al. Insulin sensitivity and insulin response in women with gestational diabetes mellitus. Horm Metab Res. 1997;29(8):393-7. [pmid: 9288577].
26 Berria R, Murgia C, Serri F, Pilia I. GDM: screening, diagnosis and management. 1997.
27 Casey BM, Lucas MJ, McIntire DD, et al. Pregnancy outcomes in women with gestational diabetes compared with the general obstetric population. Obstet Gynecol. 1997;90(6):869-73. [pmid: 9397092].
28 Lurie S, Levy R, Weiss R, et al. Low values on 50 gram glucose challenge test or oral 100 gram glucose tolerance test are associated with good perinatal outcome. J Obstet Gynaecol. 1998;18(5):451-4. [pmid: 15512142].
29 Ramachandran A, Snehalatha C, Clementina M, et al. Foetal outcome in gestational diabetes in south Indians. Diabetes Res Clin Pract. 1998;41(3):185-9. [pmid: 9829347].
30 Whitaker RC, Pepe MS, Seidel KD, et al. Gestational diabetes and the risk of offspring obesity. Pediatrics. 1998;101(2):e9. [pmid: 9445519].
31 Kitzmiller JL, Elixhauser A, Carr S, et al. Assessment of costs and benefits of management of gestational diabetes mellitus. Diabetes Care. 1998;21(Suppl 2):B123-B130. [pmid: 9704239].
32 Schafer-Graf UM, Dupak J, Vogel M, et al. Hyperinsulinism, neonatal obesity and placental immaturity in infants born to women with one abnormal glucose tolerance test value. J Perinat Med. 1998;26(1):27-36. [pmid: 9595364].
33 Major CA, Henry MJ, de VM, et al. The effects of carbohydrate restriction in patients with diet-controlled gestational diabetes. Obstet Gynecol. 1998;91(4):600-4. [pmid: 9540949].
34 Lao TT, Lee CP. Gestational ‘impaired glucose tolerance’: should the cut-off be raised to 9 mmol l(-1)?. Diabetic Med. 1998;15(1):25-9. [pmid: 9472860].
35 Moses RG, Moses J, Davis WS. Gestational diabetes: Do lean young Caucasian women need to be tested?. Diabetes Care. 1998;21(11):1803-6. [pmid: 9802724].
36 Moses RG, Moses M, Russell KG, et al. The 75-g glucose tolerance test in pregnancy - A reference range determined on a low-risk population and related to selected pregnancy outcomes. Diabetes Care. 1998;21(11):1807-11. [pmid: 9802725].
37 Lemen PM, Wigton TR, Miller-McCarthey AJ, et al. Screening for gestational diabetes mellitus in adolescent pregnancies. Am J Obstet Gynecol. 1998;178(6):1251-4. [pmid: 9662309].
38 Lauszus FF, Paludan J, Klebe JG. Birthweight in women with potential gestational diabetes mellitus - An effect of obesity rather than glucose intolerance?. Acta Obstet Gynecol Scand. 1999;78(6):520-5. [pmid: 10376862].
39 Roncaglia N, Bellini P, Arreghini A, et al. Gestational diabetes mellitus: intensive versus mild treatment. Clin Exp Obstet Gynecol. 1999;26(2):95-7. [pmid: 10459448].
40 McFarland MB, Langer O, Conway DL, et al. Dietary therapy for gestational diabetes: how long is long enough?. Obstet Gynecol. 1999;93(6):978-82. [pmid: 10362166].
41 Kvetny J, Poulsen HF, Damgaard DW. Results from screening for gestational diabetes mellitus in a Danish county. Dan Med Bull. 1999;46(1):57-9. [pmid: 10081653].
42 Shivvers SA, Lucas MJ. Gestational diabetes - Is a 50-g screening result >= 200 mg/dL diagnostic?. J Reprod Med. 1999;44(8):685-8. [pmid: 10483538].
43 Jovanovic L, Gutierrez M, Peterson CM. Chromium supplementation for women with gestational diabetes mellitus. J Trace Elem Exp Med. 1999;12(2):91-7.
44 Vohr BR, McGarvey ST, Tucker R. Effects of maternal gestational diabetes on offspring adiposity at 4-7 years of age. Diabetes Care. 1999;22(8):1284-91. [pmid: 10480772].
45 Mirghani OA, Saeed OK. A simplified management of diabetic pregnant woman. Saudi Med J. 2000;21(4):335-9. [pmid: 11533813].
46 Rae A, Bond D, Evans S, et al. A randomised controlled trial of dietary energy restriction in the management of obese women with gestational diabetes. Aust N Z J Obstet Gynaecol. 2000;40(4):416-22. [pmid: 11194427].
47 Langer O, Conway DL, Berkus MD, et al. A comparison of glyburide and insulin in women with gestational diabetes mellitus. N Engl J Med. 2000;343(16):1134-8. [pmid: 11036118].
48 Rudge MV, Calderon IM, Ramos MD, et al. Perinatal outcome of pregnancies complicated by diabetes and by maternal daily hyperglycemia not related to diabetes. A retrospective 10-year analysis. Gynecol Obstet Invest. 2000;50(2):108-12. [pmid: 10965194].
49 Rigano S, Ferrazzi E, Radaelli T, et al. Sonographic measurements of subcutaneous fetal fat in pregnancies complicated by gestational diabetes and in normal pregnancies. Croat Med J. 2000;41(3):240-4. [pmid: 10962040].
50 Bancroft K, Tuffnell DJ, Mason GC, et al. A randomised controlled pilot study of the management of gestational impaired glucose tolerance. BJOG. 2000;107(8):959-63. [pmid: 10955425].
51 Lao TT, Ho LF. Impaired glucose tolerance and pregnancy outcome in Chinese women with high body mass index. Hum Reprod. 2000;15(8):1826-9. [pmid: 10920111].
52 Simpson RW, Kast SJ. Management of gestational diabetes with a conservative insulin protocol. The Medical Journal Of Australia. 2000;172(11):537-40. [pmid: 10920751].
53 Hearty RT, Traub AI, Hadden DR. Screening for hyperglycaemia in pregnancy: analysis of two screening protocols and review of current methods. Ulster Med J. 2000;69(1):35-43. [pmid: 10881644].
54 Crowe SM, Mastrobattista JM, Monga M. Oral glucose tolerance test and the preparatory diet. Am J Obstet Gynecol. 2000;182(5):1052-4. [pmid: 10819825].
55 Wong L, Tan AS. The glucose challenge test for screening gestational diabetes in pregnant women with no risk factors. Singapore Med J. 2001;42(11):517-21. [pmid: 11876377].
56 Lauszus FF, Rasmussen OW, Henriksen JE, et al. Effect of a high monounsaturated fatty acid diet on blood pressure and glucose metabolism in women with gestational diabetes mellitus. Eur J Clin Nutr. 2001;55(6):436-43. [pmid: 11423920].
57 Jensen DM, Damm P, Sorensen B, et al. Clinical impact of mild carbohydrate intolerance in pregnancy: a study of 2904 nondiabetic Danish women with risk factors for gestational diabetes mellitus. Am J Obstet Gynecol. 2001;185(2):413-9. [pmid: 11518901].
58 MacNeill S, Dodds L, Hamilton DC, et al. Rates and risk factors for recurrence of gestational diabetes. Diabetes Care. 2001;24(4):659-62. [pmid: 11315827].
59 Ray JG, Vermeulen MJ, Shapiro JL, et al. Maternal and neonatal outcomes in pregestational and gestational diabetes mellitus, and the influence of maternal obesity and weight gain: the DEPOSIT study. Diabetes Endocrine Pregnancy Outcome Study in Toronto. QJM. 2001;94(7):347-56. [pmid: 11435630].
60 Xiong X, Saunders LD, Wang FL, et al. Gestational diabetes mellitus: prevalence, risk factors, maternal and infant outcomes. Int J Gynaecol Obstet. 2001;75(3):221-8. [pmid: 11728481].
61 Baliutaviciene D, Petrenko V, Zalinkevicius R. Selective or universal diagnostic testing for gestational diabetes mellitus. Int J Gynaecol Obstet. 2002;78(3):207-11. [pmid: 12384265].
62 Gezer A, Esen F, Mutlu H, et al. Prognosis of patients with positive screening but negative diagnostic test for gestational diabetes. Arch Gynecol Obstet. 2002;266(4):201-4. [pmid: 12192479].
63 Di CG, Volpe L, Casadidio I, et al. Universal screening and intensive metabolic management of gestational diabetes: cost-effectiveness in Italy. Acta Diabetol. 2002;39(2):69-73. [pmid: 12120916].
64 Homko CJ, Sivan E, Reece EA. The impact of self-monitoring of blood glucose on self-efficacy and pregnancy outcomes in women with diet-controlled gestational diabetes. Diabetes Educ. 2002;28(3):435-43. [pmid: 12073958].
65 Rumbold AR, Crowther CA. Women's experiences of being screened for gestational diabetes mellitus. Aust N Z J Obstet Gynaecol. 2002;42(2):131-7. [pmid: 12069138].
66 Pullen F, Grenfell A. The diagnosis of gestational diabetes in a multiethnic population: Which diagnostic criteria should be used with respect to maternal outcome?. Pract Diabetes Int. 2002;29(9):279-82.
67 Pettitt DJ, Ospina P, Jovanovic L. Comparison of an insulin analog, insulin aspart, and regular human insulin with no insulin in gestational diabetes mellitus. Diabetologia. 2002;45(Suppl 2):A254-A255.
68 Chen R, Yogev Y, Ben-Haroush A, et al. Continuous glucose monitoring for the evaluation and improved control of gestational diabetes mellitus. J Matern Fetal Neonatal Med. 2003;14(4):256-60. [pmid: 14738172].
69 Mecacci F, Carignani L, Cioni R, et al. Maternal metabolic control and perinatal outcome in women with gestational diabetes treated with regular or lispro insulin: comparison with non-diabetic pregnant women. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):19-24. [pmid: 14557006].
70 Gruendhammer M, Brezinka C, Lechleitner M. The number of abnormal plasma glucose values in the oral glucose tolerance test and the feto-maternal outcome of pregnancy. Eur J Obstet Gynecol Reprod Biol. 2003;108(2):131-6. [pmid: 12781399].
71 Kulkarni M, Jones KD, Newbold S. Screening for gestational diabetes: a retrospective audit. J Obstet Gynaecol. 2003;23(2):160-2. [pmid: 12745560].
72 Daniells S, Grenyer BFS, Davis WS, et al. Gestational diabetes mellitus: Is a diagnosis associated with an increase in maternal anxiety and stress in the short and intermediate term?. Diabetes Care. 2003;26(2):385-9. [pmid: 12547867].
73 Saldana TM, Siega-Riz AM, Adair LS, et al. The association between impaired glucose tolerance and birth weight among black and white women in central North Carolina. Diabetes Care. 2003;26(3):656-61. [pmid: 12610017].
74 Sunsaneevithayakul P, Ruangvutilert P, Sutanthavibul A, et al. Effect of 3-day intensive dietary therapy during admission in women after diagnosis of gestational diabetes mellitus. J Med Assoc Thai. 2004;87(9):1022-8. [pmid: 15516001].
75 Ertunc D, Tok E, Dilek U, et al. The effect of carbohydrate intolerance on neonatal birth weight in pregnant women without gestational diabetes mellitus. Ann Saudi Med. 2004;24(4):280-3. [pmid: 15387495].
76 Bonomo M, Cetin I, Pisoni MP, et al. Flexible treatment of gestational diabetes modulated on ultrasound evaluation of intrauterine growth: a controlled randomized clinical trial. Diabetes Metab. 2004;30(3):237-44. [pmid: 15223975].
77 Maser RE, Lenhard MJ, Henderson BC, et al. Detection of subsequent episodes of gestational diabetes mellitus: a need for specific guidelines. J Diabetes Complications. 2004;18(2):86-90. [pmid: 15120702].
78 Conway DL, Gonzales O, Skiver D. Use of glyburide for the treatment of gestational diabetes: the San Antonio experience. J Matern Fetal Neonatal Med. 2004;15(1):51-5. [pmid: 15101612].
79 Brankston GN, Mitchell BF, Ryan EA, et al. Resistance exercise decreases the need for insulin in overweight women with gestational diabetes mellitus. Am J Obstet Gynecol. 2004;190(1):188-93. [pmid: 14749658].
80 Schaefer-Graf UM, Kjos SL, Fauzan OH, et al. A randomized trial evaluating a predominantly fetal growth-based strategy to guide management of gestational diabetes in Caucasian women. Diabetes Care. 2004;27(2):297-302. [pmid: 14747203].
81 Lauenborg J, Hansen T, Jensen DM, et al. Increasing Incidence of Diabetes after Gestational Diabetes: A long-term follow-up in a Danish population. Diabetes Care. 2004;27(5):1194-9. [pmid: 15111544].
82 Kim C, Brawarsky P, Jackson RA, et al. Changes in health status experienced by women with gestational diabetes and pregnancy-induced hypertensive disorders. J Womens Health. 2005;14(8):729-36.
83 Bertini AM, Silva JC, Taborda W, et al. Perinatal outcomes and the use of oral hypoglycemic agents. J Perinat Med. 2005;33(6):519-23. [pmid: 16318615].
84 Sharpe PB, Chan A, Haan EA, et al. Maternal diabetes and congenital anomalies in South Australia 1986-2000: a population-based cohort study. Birth Defects Res Part A Clin Mol Teratol. 2005;73(9):605-11. [pmid: 16007590].
85 Leipold H, Worda C, Gruber CJ, et al. Large-for-gestational-age newborns in women with insulin-treated gestational diabetes under strict metabolic control. Wien Klin Wochenschr. 2005;117(15-16):521-5. [pmid: 16160802].
86 Chan BC, Lao TT. Gestational diabetes mellitus in women in the fourth decade--is treatment worthwhile?. Gynecol Obstet Invest. 2005;60(2):112-6. [pmid: 15886486].
87 Jacobson GF, Ramos GA, Ching JY, et al. Comparison of glyburide and insulin for the management of gestational diabetes in a large managed care organization. Am J Obstet Gynecol. 2005;193(1):118-24. [pmid: 16021069].
88 Barahona MJ, Sucunza N, Garcia-Patterson A, et al. Period of gestational diabetes mellitus diagnosis and maternal and fetal morbidity. Acta Obstet Gynecol Scand. 2005;84(7):622-7. [pmid: 15954869].
89 Yogev Y, Langer O, Xenakis EM, et al. The association between glucose challenge test, obesity and pregnancy outcome in 6390 non-diabetic women. J Matern Fetal Neonatal Med. 2005;17(1):29-34. [pmid: 15804783].
90 Weisz B, Shrim A, Homko CJ, et al. One hour versus two hours postprandial glucose measurement in gestational diabetes: a prospective study. J Perinatol. 2005;25(4):241-4. [pmid: 15605070].
91 Ho LF, Benzie IF, Lao TT. Relationship between caloric intake and pregnancy outcome in diet-treated gestational diabetes mellitus. Nurs Health Sci. 2005;7(1):15-20. [pmid: 15670002].
92 Langer O, Yogev Y, Xenakis EM, et al. Insulin and glyburide therapy: dosage, severity level of gestational diabetes, and pregnancy outcome. Am J Obstet Gynecol. 2005;192(1):134-9. [pmid: 15672015].
93 Keshavarz M, Cheung NW, Babaee GR, et al. Gestational diabetes in Iran: incidence, risk factors and pregnancy outcomes. Diabetes Res Clin Pract. 2005;69(3):279-86. [pmid: 16098925].
94 Ezimokhai M, Joseph A, Bradley-Watson P. Audit of pregnancies complicated by diabetes from one center five years apart with selective versus universal screening. Ann N Y Acad Sci. 2006;1084:132-40. [pmid: 17151297].
95 Li K, Yang HX. Value of fructosamine measurement in pregnant women with abnormal glucose tolerance. Chin Med J. 2006;119(22):1861-5. [pmid: 17134583].
96 Thanasuan S, Borriboonhirunsarn D. Incidence of gestational diabetes mellitus among pregnant women with one abnormal value of oral glucose tolerance test. J Med Assoc Thai. 2006;89(8):1109-14. [pmid: 17048417].
97 Rochon M, Rand L, Roth L, et al. Glyburide for the management of gestational diabetes: risk factors predictive of failure and associated pregnancy outcomes. Am J Obstet Gynecol. 2006;195(4):1090-4. [pmid: 17000241].
98 Reader D, Splett P, Gunderson EP, et al. Impact of gestational diabetes mellitus nutrition practice guidelines implemented by registered dietitians on pregnancy outcomes. J Am Diet Assoc. 2006;106(9):1426-33. [pmid: 16963348].
99 Shefali AK, Kavitha M, Deepa R, et al. Pregnancy outcomes in pre-gestational and gestational diabetic women in comparison to non-diabetic women--A prospective study in Asian Indian mothers (CURES-35). J Assoc Physicians India. 2006;54:613-8. [pmid: 16941791].
100 Chandna A, Zuberi LM, Munim S. Threshold values for the glucose challenge test in pregnancy. Int J Gynaecol Obstet. 2006;94(2):119-20. [pmid: 16777106].
101 Kahn BF, Davies JK, Lynch AM, et al. Predictors of glyburide failure in the treatment of gestational diabetes. Obstet Gynecol. 2006;107(6):1303-9. [pmid: 16738156].
102 Dudhbhai M, Lim L, Bombard A, et al. Characteristics of patients with abnormal glucose challenge test and normal oral glucose tolerance test results: comparison with normal and gestational diabetic patients. Am J Obstet Gynecol. 2006;194(5):e42-e45. [pmid: 16647897].
103 McLaughlin GB, Cheng YW, Caughey AB. Women with one elevated 3-hour glucose tolerance test value: are they at risk for adverse perinatal outcomes?. Am J Obstet Gynecol. 2006;194(5):e16-e19. [pmid: 16647890].
104 Sunsaneevithayakul P, Kanokpongsakdi S, Sutanthavibul A, et al. Result of ambulatory diet therapy in gestational diabetes mellitus. J Med Assoc Thai. 2006;89(1):8-12. [pmid: 16583574].
105 D'Anna R, Baviera G, De VA, et al. C-reactive protein as an early predictor of gestational diabetes mellitus. J Reprod Med. 2006;51(1):55-8. [pmid: 16482778].
106 Nordin NM, Wei JW, Naing NN, et al. Comparison of maternal-fetal outcomes in gestational diabetes and lesser degrees of glucose intolerance. J Obstet Gynaecol Res. 2006;32(1):107-14. [pmid: 16445535].
107 Weijers RN, Bekedam DJ, Goldschmidt HM, et al. The clinical usefulness of glucose tolerance testing in gestational diabetes to predict early postpartum diabetes mellitus. Clin Chem Lab Med. 2006;44(1):99-104. [pmid: 16375594].
108 Cosson E, Benchimol M, Carbillon L, et al. Universal rather than selective screening for gestational diabetes mellitus may improve fetal outcomes. Diabetes Metab. 2006;32(2):140-6. [pmid: 16735962].
109 Moore LE, Briery CM, Clokey D, et al. Metformin and insulin in the management of gestational diabetes mellitus: preliminary results of a comparison. J Reprod Med. 2007;52(11):1011-5. [pmid: 18161398].
110 Most O, Langer O. GDM women in good glycemic control: which meal-related measure enhances fetal well-being?. J Perinat Med. 2007;35(6):481-5. [pmid: 18052834].
111 Cypryk K, Kaminska P, Kosinski M, et al. A comparison of the effectiveness, tolerability and safety of high and low carbohydrate diets in women with gestational diabetes. Endokrynol Pol. 2007;58(4):314-9. [pmid: 18058723].
112 Cheng YW, McLaughlin GB, Esakoff TF, et al. Glucose challenge test: screening threshold for gestational diabetes mellitus and associated outcomes. J Matern Fetal Neonatal Med. 2007;20(12):903-8. [pmid: 18050020].
113 Krishnaveni GV, Hill JC, Veena SR, et al. Gestational diabetes and the incidence of diabetes in the 5 years following the index pregnancy in South Indian women. Diabetes Res Clin Pract. 2007;78(3):398-404. [pmid: 17640759].
114 Virally M, Laloi-Michelin M, Meas T, et al. Occurrence of gestational diabetes mellitus, maternal and fetal outcomes beyond the 28th week of gestation in women at high risk of gestational diabetes. A prospective study. Diabetes Metab. 2007;33(4):290-5. [pmid: 17652001].
115 Pettitt DJ, Ospina P, Howard C, et al. Efficacy, safety and lack of immunogenicity of insulin aspart compared with regular human insulin for women with gestational diabetes mellitus. Diabetic Med. 2007;24(10):1129-35. [pmid: 17888133].
116 Yogev Y, Langer O. Spontaneous preterm delivery and gestational diabetes: the impact of glycemic control. Arch Gynecol Obstet. 2007;276(4):361-5. [pmid: 17429669].
117 Todorova K, Palaveev O, Petkova VB, et al. A pharmacoeconomical model for choice of a treatment for pregnant women with gestational diabetes. Acta Diabetol. 2007;44(3):144-8. [pmid: 17721753].
118 Dodd JM, Crowther CA, Antoniou G, et al. Screening for gestational diabetes: the effect of varying blood glucose definitions in the prediction of adverse maternal and infant health outcomes. Aust N Z J Obstet Gynaecol. 2007;47(4):307-12. [pmid: 17627686].
119 Rowan JA, MiG I. A trial in progress: gestational diabetes. Treatment with metformin compared with insulin (the Metformin in Gestational Diabetes [MiG] trial). [Erratum appears in Diabetes Care. 2007 Dec;30(12):3154]. Diabetes Care. 2007;30(Suppl 2):S214-S219. [pmid: 17596475].
120 Di CG, Seghieri G, Lencioni C, et al. Normal glucose tolerance and gestational diabetes mellitus: what is in between?. Diabetes Care. 2007;30(7):1783-8. [pmid: 17416793].
121 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
122 Artal R, Catanzaro RB, Gavard JA, et al. A lifestyle intervention of weight-gain restriction: diet and exercise in obese women with gestational diabetes mellitus. Appl Physiol Nutr Metab. 2007;32(3):596-601. [pmid: 17510701].
123 Kestila KK, Ekblad UU, Ronnemaa T. Continuous glucose monitoring versus self-monitoring of blood glucose in the treatment of gestational diabetes mellitus. Diabetes Res Clin Pract. 2007;77(2):174-9. [pmid: 17234297].
124 Ramos GA, Jacobson GF, Kirby RS, et al. Comparison of glyburide and insulin for the management of gestational diabetics with markedly elevated oral glucose challenge test and fasting hyperglycemia. J Perinatol. 2007;27(5):262-7. [pmid: 17363911].
125 Simmons D. Relationship between maternal glycaemia and birth weight in glucose-tolerant women from different ethnic groups in New Zealand. Diabetic Med. 2007;24(3):240-4. [pmid: 17263762].
126 Lee AJ, Hiscock RJ, Wein P, et al. Gestational diabetes mellitus: clinical predictors and long-term risk of developing type 2 diabetes: a retrospective cohort study using survival analysis. Diabetes Care. 2007;30(4):878-83. [pmid: 17392549].
127 Price N, Bartlett C, Gillmer M. Use of insulin glargine during pregnancy: a case-control pilot study. BJOG. 2007;114(4):453-7. [pmid: 17261126].
128 Berg M, Adlerberth A, Sultan B, et al. Early random capillary glucose level screening and multidisciplinary antenatal teamwork to improve outcome in gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2007;86(3):283-90. [pmid: 17364301].
129 Sinclair BA, Rowan JA, Hainsworth OT. Macrosomic infants are not all equal. Aust N Z J Obstet Gynaecol. 2007;47(2):101-5. [pmid: 17355297].
130 Koklanaris N, Bonnano C, Seubert D, et al. Does raising the glucose challenge test threshold impact birthweight in Asian gravidas?. J Perinat Med. 2007;35(2):100-3. [pmid: 17302513].
131 Anjalakshi C, Balaji V, Balaji MS, et al. A prospective study comparing insulin and glibenclamide in gestational diabetes mellitus in Asian Indian women. Diabetes Res Clin Pract. 2007;76(3):474-5. [pmid: 17113179].
132 Jasbinder K, Shivani J, Anju H, et al. Pregnancy outcome in gestational diabetes mellitus: continued risk related to FBS levels. Diabetes Res Clin Pract. 2007;78(2):302-3. [pmid: 17490780].
133 Anderberg E, Kallen K, Berntorp K, et al. A simplified oral glucose tolerance test in pregnancy: compliance and results. Acta Obstet Gynecol Scand. 2007;86(12):1432-6. [pmid: 17963051].
134 Ozcimen EE, Uckuyu A, Ciftci FC, et al. Diagnosis of gestational diabetes mellitus by use of the homeostasis model assessment-insulin resistance index in the first trimester. Gynecol Endocrinol. 2008;24(4):224-9. [pmid: 18382910].
135 Tam WH, Ma RC, Yang X, et al. Glucose intolerance and cardiometabolic risk in children exposed to maternal gestational diabetes mellitus in utero. Pediatrics. 2008;122(6):1229-34. [pmid: 19047239].
136 Akinci B, Celtik A, Yener S, et al. Is fasting glucose level during oral glucose tolerance test an indicator of the insulin need in gestational diabetes?. Diabetes Res Clin Pract. 2008;82(2):219-25. [pmid: 18768235].
137 Holt RI, Clarke P, Parry EC, et al. The effectiveness of glibenclamide in women with gestational diabetes. Diabetes Obes Metab. 2008;10(10):906-11. [pmid: 18093212].
138 Snapp CA, Donaldson SK. Gestational diabetes mellitus: physical exercise and health outcomes. Biol Res Nurs. 2008;10(2):145-55. [pmid: 18829598].
139 Ju H, Rumbold AR, Willson KJ, et al. Borderline gestational diabetes mellitus and pregnancy outcomes. BMC Pregnancy Childbirth. 2008;8:31. [pmid: 18664297].
140 Suhonen L, Hiilesmaa V, Kaaja R, et al. Detection of pregnancies with high risk of fetal macrosomia among women with gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2008;87(9):940-5. [pmid: 18728914].
141 Mendelson SG, Neese-Smith D, Koniak-Griffin D, et al. A community-based parish nurse intervention program for Mexican American women with gestational diabetes. J Obstet Gynecol & Neonatal Nurs. 2008;37(4):415-25.
142 Gumus II, Turhan NO. Are patients with positive screening but negative diagnostic test for gestational diabetes under risk for adverse pregnancy outcome?. J Obstet Gynaecol Res. 2008;34(3):359-63. [pmid: 18588612].
143 Lee H, Jang HC, Park HK, et al. Prevalence of type 2 diabetes among women with a previous history of gestational diabetes mellitus. Diabetes Res Clin Pract. 2008;81(1):124-9. [pmid: 18456364].
144 Rowan JA, Hague WM, Gao W, et al. Metformin versus insulin for the treatment of gestational diabetes. [Erratum appears in N Engl J Med. 2008 Jul 3;359(1):106]. N Engl J Med. 2008;358(19):2003-15. [pmid: 18463376].
145 Grotegut CA, Tatineni H, Dandolu V, et al. Obstetric outcomes with a false-positive one-hour glucose challenge test by the Carpenter-Coustan criteria. J Matern Fetal Neonatal Med. 2008;21(5):315-20. [pmid: 18446658].
146 Negrato CA, Jovanovic L, Tambascia MA, et al. Mild gestational hyperglycaemia as a risk factor for metabolic syndrome in pregnancy and adverse perinatal outcomes. Diabetes Metab Res Rev. 2008;24(4):324-30. [pmid: 18254163].
147 Savona-Ventura C, Chircop M. Significant thresholds for the 75-g oral glucose tolerance test in pregnancy. J Diabetes Complications. 2008;22(3):178-80. [pmid: 18413221].
148 Lapolla A, Dalfra MG, Mello G, et al. Early detection of insulin sensitivity and beta-cell function with simple tests indicates future derangements in late pregnancy. J Clin Endocrinol Metab. 2008;93(3):876-80. [pmid: 18089696].
149 Hawkins JS, Lo JY, Casey BM, et al. Diet-treated gestational diabetes mellitus: comparison of early vs routine diagnosis. Am J Obstet Gynecol. 2008;198(3):287-e1-6. [pmid: 18313450].
150 Keely EJ, Malcolm JC, Hadjiyannakis S, et al. Prevalence of metabolic markers of insulin resistance in offspring of gestational diabetes pregnancies. Pediatr Diabetes. 2008;9(1):53-9. [pmid: 18036135].
151 Elnour AA, El Mugammar IT, Jaber T, et al. Pharmaceutical care of patients with gestational diabetes mellitus. Journal of Evaluation in Clinical Practice. 2008;14(1):131-40. [pmid: 18211656].
152 Elnour AA, McElnay JC. Antenatal oral glucose-tolerance test values and pregnancy outcomes. Int J Pharm Pract. 2008;16(3):189-97.
153 Carr DB, Newton KM, Utzschneider KM, et al. Modestly elevated glucose levels during pregnancy are associated with a higher risk of future diabetes among women without gestational diabetes mellitus. Diabetes Care. 2008;31(5):1037-9. [pmid: 18223032].
154 Jensen DM, Korsholm L, Ovesen P, et al. Adverse pregnancy outcome in women with mild glucose intolerance: is there a clinically meaningful threshold value for glucose?. Acta Obstet Gynecol Scand. 2008;87(1):59-62. [pmid: 18158628].
155 Seshiah V, Balaji V, Balaji MS, et al. Prevalence of gestational diabetes mellitus in South India (Tamil Nadu)--a community based study. J Assoc Physicians India. 2008;56:329-33. [pmid: 18700640].
156 Rai L, Meenakshi D, Kamath A. Metformin--a convenient alternative to insulin for Indian women with diabetes in pregnancy. Indian J Med Sci. 2009;63(11):491-7. [pmid: 20075550].
157 Hebert MF, Ma X, Naraharisetti SB, et al. Are we optimizing gestational diabetes treatment with glyburide? The pharmacologic basis for better clinical practice. Clin Pharmacol Ther. 2009;85(6):607-14. [pmid: 19295505].
158 Negrato CA, Jovanovic L, Tambascia MA, et al. Association between insulin resistance, glucose intolerance, and hypertension in pregnancy. Metab Syndr Relat Disord. 2009;7(1):53-9. [pmid: 18847384].
159 Segregur J, Bukovic D, Milinovic D, et al. Fetal macrosomia in pregnant women with gestational diabetes. Coll Antropol. 2009;33(4):1121-7. [pmid: 20102057].
160 Pedula KL, Hillier TA, Schmidt MM, et al. Ethnic differences in gestational oral glucose screening in a large US population. Ethn Dis. 2009;19(4):414-9. [pmid: 20073142].
161 Persson M, Winkvist A, Mogren I. Surprisingly low compliance to local guidelines for risk factor based screening for gestational diabetes mellitus - A population-based study. BMC Pregnancy Childbirth. 2009;9:53. [pmid: 19917091].
162 Perichart-Perera O, Balas-Nakash M, Parra-Covarrubias A, et al. A medical nutrition therapy program improves perinatal outcomes in Mexican pregnant women with gestational diabetes and type 2 diabetes mellitus. Diabetes Educ. 2009;35(6):1004-13. [pmid: 19696205].
163 Wroblewska-Seniuk K, Wender-Ozegowska E, Szczapa J. Long-term effects of diabetes during pregnancy on the offspring. Pediatr Diabetes. 2009;10(7):432-40. [pmid: 19476566].
164 Balani J, Hyer SL, Rodin DA, et al. Pregnancy outcomes in women with gestational diabetes treated with metformin or insulin: a case-control study. Diabetic Med. 2009;26(8):798-802. [pmid: 19709150].
165 Retnakaran R, Shah BR. Abnormal screening glucose challenge test in pregnancy and future risk of diabetes in young women. Diabetic Med. 2009;26(5):474-7. [pmid: 19646185].
166 Lapolla A, Dalfra MG, Bonomo M, et al. Gestational diabetes mellitus in Italy: a multicenter study. Eur J Obstet Gynecol Reprod Biol. 2009;145(2):149-53. [pmid: 19467766].
167 Madarasz E, Tamas G, Tabak AG, et al. Carbohydrate metabolism and cardiovascular risk factors 4 years after a pregnancy complicated by gestational diabetes. Diabetes Res Clin Pract. 2009;85(2):197-202. [pmid: 19481830].
168 Lin CH, Wen SF, Wu YH, et al. Using the 100-g oral glucose tolerance test to predict fetal and maternal outcomes in women with gestational diabetes mellitus. Chang Gung Medical Journal. 2009;32(3):283-9. [pmid: 19527607].
169 Esakoff TF, Cheng YW, Sparks TN, et al. The association between birthweight 4000 g or greater and perinatal outcomes in patients with and without gestational diabetes mellitus. Am J Obstet Gynecol. 2009;200(6):672-4. [pmid: 19376489].
170 Moses RG, Barker M, Winter M, et al. Can a low-glycemic index diet reduce the need for insulin in gestational diabetes mellitus? A randomized trial. Diabetes Care. 2009;32(6):996-1000. [pmid: 19279301].
171 Barrett HL, Morris J, McElduff A. Watchful waiting: a management protocol for maternal glycaemia in the peripartum period. Aust N Z J Obstet Gynaecol. 2009;49(2):162-7. [pmid: 19432604].
172 Lain KY, Garabedian MJ, Daftary A, et al. Neonatal adiposity following maternal treatment of gestational diabetes with glyburide compared with insulin. Am J Obstet Gynecol. 2009;200(5):501-6. [pmid: 19375570].
173 Karmon A, Levy A, Holcberg G, et al. Decreased perinatal mortality among women with diet-controlled gestational diabetes mellitus. Int J Gynaecol Obstet. 2009;104(3):199-202. [pmid: 19189868].
174 Most OL, Kim JH, Arslan AA, et al. Maternal and neonatal outcomes in early glucose tolerance testing in an obstetric population in New York city. J Perinat Med. 2009;37(2):114-7. [pmid: 19143578].
175 Kucuk M, Doymaz F. Placental weight and placental weight-to-birth weight ratio are increased in diet- and exercise-treated gestational diabetes mellitus subjects but not in subjects with one abnormal value on 100-g oral glucose tolerance test. J Diabetes Complications. 2009;23(1):25-31. [pmid: 18413216].
176 Pawelec M, Karmowski A, Krzemieniewska J, et al. The clinical and financial effects of replacing the 1 h 50 g screening test for gestational diabetes mellitus by the stick method. Adv Clin Exp Med. 2009;18(6):601-7.
177 Hossein-nezhad A, Mirzaei K, Maghbooli Z, et al. Maternal glycemic status in GDM patients after delivery. Iran J Diabetes Lipid Disord. 2009;8(1):95-104.
178 Clausen TD, Mathiesen ER, Hansen T, et al. Overweight and the metabolic syndrome in adult offspring of women with diet-treated gestational diabetes mellitus or type 1 diabetes. J Clin Endocrinol Metab. 2009;94(7):2464-70. [pmid: 19417040].
179 Riskin-Mashiah S, Younes G, Damti A, et al. First-Trimester Fasting Hyperglycemia and Adverse Pregnancy Outcomes. Diabetes Care. 2009;32(9):1639-43. [pmid: 19549728].
180 Herring SJ, Oken E, Rifas-Shiman SL, et al. Weight gain in pregnancy and risk of maternal hyperglycemia. Am J Obstet Gynecol. 2009;201(1):61-7. [pmid: 19371858].
181 Chen YZ, Quick WW, Yang WY, et al. Cost of Gestational Diabetes Mellitus in the United States in 2007. Population Health Management. 2009;12(3):165-74. [pmid: 19534581].
182 Hedderson MM, Darbinian JA, Ferrara A. Disparities in the risk of gestational diabetes by race-ethnicity and country of birth. Paediatr Perinat Epidemiol. 2010;24(5):441-8. [pmid: 20670225].
183 de Barros MC, Lopes MA, Francisco RP, et al. Resistance exercise and glycemic control in women with gestational diabetes mellitus. Am J Obstet Gynecol. 2010;203(6):556-e1-6. [pmid: 20864072].
184 Karcaaltincaba D, Yalvac S, Kandemir O, et al. Glycosylated hemoglobin level in the second trimester predicts birth weight and amniotic fluid volume in non-diabetic pregnancies with abnormal screening test. J Matern Fetal Neonatal Med. 2010;23(10):1193-9. [pmid: 20059437].
185 Silva JC, Pacheco C, Bizato J, et al. Metformin compared with glyburide for the management of gestational diabetes. Int J Gynaecol Obstet. 2010;111(1):37-40. [pmid: 20542272].
186 Anderberg E, Kallen K, Berntorp K. The impact of gestational diabetes mellitus on pregnancy outcome comparing different cut-off criteria for abnormal glucose tolerance. Acta Obstet Gynecol Scand. 2010;89(12):1532-7. [pmid: 21050147].
187 Kvehaugen AS, Andersen LF, Staff AC. Anthropometry and cardiovascular risk factors in women and offspring after pregnancies complicated by preeclampsia or diabetes mellitus. Acta Obstet Gynecol Scand. 2010;89(11):1478-85. [pmid: 20955102].
188 Pugh SK, Poole AT, Hill JB, et al. Abnormal 1 hour glucose challenge test followed by a normal 3 hour glucose tolerance test: does it identify adverse pregnancy outcome?. J Miss State Med Assoc. 2010;51(1):3-6. [pmid: 20827864].
189 Balaji V, Balaji MS, Alexander C, et al. Premixed insulin aspart 30 (Biasp 30) vs. premixed human insulin 30 (BHI 30) in gestational diabetes mellitus - a pilot study. J Assoc Physicians India. 2010;58:99-101. [pmid: 20653150].
190 Barakat MN, Youssef RM, Al-Lawati JA. Pregnancy outcomes of diabetic women: charting Oman's progress towards the goals of the Saint Vincent Declaration. Ann Saudi Med. 2010;30(4):265-70. [pmid: 20622342].
191 Negrato CA, Rafacho A, Negrato G, et al. Glargine vs. NPH insulin therapy in pregnancies complicated by diabetes: an observational cohort study. Diabetes Res Clin Pract. 2010;89(1):46-51. [pmid: 20378197].
192 Fadl HE, Ostlund IK, Magnuson AF, et al. Maternal and neonatal outcomes and time trends of gestational diabetes mellitus in Sweden from 1991 to 2003. Diabetic Med. 2010;27(4):436-41. [pmid: 20536516].
193 Flores-Le Roux JA, Chillaron JJ, Goday A, et al. Peripartum metabolic control in gestational diabetes. Am J Obstet Gynecol. 2010;202(6):568-e1-6. [pmid: 20231009].
194 Geifman-Holtzman O, Machtinger R, Spiliopoulos M, et al. The clinical utility of oral glucose tolerance test at term: can it predict fetal macrosomia?. Arch Gynecol Obstet. 2010;281(5):817-21. [pmid: 19593579].
195 Buscicchio G, Gentilucci L, Giannubilo SR, et al. Computerized analysis of fetal heart rate in pregnancies complicated by gestational diabetes mellitus. Gynecol Endocrinol. 2010;26(4):270-4. [pmid: 19757245].
196 Hamilton JK, Odrobina E, Yin J, et al. Maternal insulin sensitivity during pregnancy predicts infant weight gain and adiposity at 1 year of age. Obesity. 2010;18(2):340-6. [pmid: 19661962].
197 Rowan JA, Gao W, Hague WM, et al. Glycemia and its relationship to outcomes in the metformin in gestational diabetes trial. Diabetes Care. 2010;33(1):9-16. [pmid: 19846793].
198 Moore LE, Clokey D, Rappaport VJ, et al. Metformin compared with glyburide in gestational diabetes: a randomized controlled trial. Obstet Gynecol. 2010;115(1):55-9. [pmid: 20027034].
199 Chodick G, Elchalal U, Sella T, et al. The risk of overt diabetes mellitus among women with gestational diabetes: A population-based study. Diabetic Med. 2010;27(7):779-85. [pmid: 20636958].
200 Elkind-Hirsch KE, Ogden BW, Darensbourg CJ, et al. Clinical assessment of insulin action during late pregnancy in women at risk for gestational diabetes: Association of maternal glycemia with perinatal outcome. Int J Diabetes Mellitus. 2010;2(1):3-9.
201 Perez-Ferre N, Galindo M, Fernandez MD, et al. The outcomes of gestational diabetes mellitus after a telecare approach are not inferior to traditional outpatient clinic visits. Int J Endocrinol. 2010:386941. [pmid: 20628517].
202 Hedderson MM, Gunderson EP, Ferrara A. Gestational weight gain and risk of gestational diabetes mellitus. Obstet Gynecol. 2010;115(3):597-604. [pmid: 20177292].
203 O'Sullivan EP, Avalos G, O'Reilly M, et al. Atlantic Diabetes in Pregnancy (DIP): the prevalence and outcomes of gestational diabetes mellitus using new diagnostic criteria. Diabetologia. 2011;54(7):1670-5. [pmid: 21494772].
204 Ehrlich SF, Crites YM, Hedderson MM, et al. The risk of large for gestational age across increasing categories of pregnancy glycemia. Am J Obstet Gynecol. 2011;204(3):240-e1-6. [pmid: 21247550].
205 Corrado F, D'Anna R, Di VG, et al. The effect of myoinositol supplementation on insulin resistance in patients with gestational diabetes. Diabetic Med. 2011;28(8):972-5. [pmid: 21414183].
206 Yogev Y, Melamed N, Chen R, et al. Glyburide in gestational diabetes--prediction of treatment failure. J Matern Fetal Neonatal Med. 2011;24(6):842-6. [pmid: 21067291].
207 Ouzounian JG, Rosenheck R, Lee RH, et al. One-hour post-glucola results and pre-pregnancy body mass index are associated with the need for insulin therapy in women with gestational diabetes. J Matern Fetal Neonatal Med. 2011;24(5):718-22. [pmid: 20937005].
208 Korpi-Hyovalti EA, Laaksonen DE, Schwab US, et al. Feasibility of a lifestyle intervention in early pregnancy to prevent deterioration of glucose tolerance. BMC Public Health. 2011;11:179. [pmid: 21429234].
209 Riskin-Mashiah S, Damti A, Younes G, et al. Normal fasting plasma glucose levels during pregnancy: a hospital-based study. J Perinat Med. 2011;39(2):209-11. [pmid: 21241203].
210 Kosus A, Kosus N, Turhan NO. Assessment of cardiomyopathy in fetuses of women with false positive oral glucose loading test. Eur J Obstet Gynecol Reprod Biol. 2011;154(1):37-9. [pmid: 20855145].
211 Grant SM, Wolever TM, O'Connor DL, et al. Effect of a low glycaemic index diet on blood glucose in women with gestational hyperglycaemia. Diabetes Res Clin Pract. 2011;91(1):15-22. [pmid: 21094553].
212 Deierlein AL, Siega-Riz AM, Chantala K, et al. The association between maternal glucose concentration and child BMI at age 3 years. Diabetes Care. 2011;34(2):480-4. [pmid: 21216858].
213 Nanda S, Savvidou M, Syngelaki A, et al. Prediction of gestational diabetes mellitus by maternal factors and biomarkers at 11 to 13 weeks. Prenat Diagn. 2011;31(2):135-41. [pmid: 21268030].
214 Yee LM, Cheng YW, Liddell J, et al. 50-Gram glucose challenge test: Is it indicative of outcomes in women without gestational diabetes mellitus?. J Matern Fetal Neonatal Med. 2011;24(9):1102-6. [pmid: 21261449].
215 Kaymak O, Iskender CT, Ustunyurt E, et al. Retrospective evaluation of perinatal outcome in women with mild gestational hyperglycemia. J Obstet Gynaecol. 2011;37(8):986-91.
216 Jovanovic L, Pettitt D. Frequent monitoring of a1c during pregnancy as a treatment tool to guide therapy. Diabetes Technol Ther. 2011;34(1):53-4.
217 Durnwald CP, Mele L, Spong CY, et al. Glycemic characteristics and neonatal outcomes of women treated for mild gestational diabetes. Obstet Gynecol. 2011;117(4):819-27. [pmid: 21422852].
218 Ijas H, Vaarasmaki M, Morin-Papunen L, et al. Metformin should be considered in the treatment of gestational diabetes: a prospective randomised study. BJOG. 2011;118(7):880-5. [pmid: 21083860].
219 Balaji V, Balaji M, Anjalakshi C, et al. Diagnosis of gestational diabetes mellitus in Asian-Indian women. Indian J Endocrinol Metab. 2011;15(3):187-90. [pmid: 21897895].
220 Anderberg E, Landin-Olsson M, Kalen J, et al. Prevalence of impaired glucose tolerance and diabetes after gestational diabetes mellitus comparing different cut-off criteria for abnormal glucose tolerance during pregnancy. Acta Obstet Gynecol Scand. 2011;90(11):1252-8. [pmid: 21679163].
221 Louie JC, Markovic TP, Perera N, et al. Randomized Controlled Trial Investigating the Effects of a Low-Glycemic Index Diet on Pregnancy Outcomes in Gestational Diabetes Mellitus. Diabetes Care. 2011;34(11):2341-6. [pmid: 21900148].
222 Saxena P, Tyagi S, Prakash A, et al. Pregnancy outcome of women with gestational diabetes in a tertiary level hospital of north India. Indian J Community Med. 2011;36(2):120-3. [pmid: 21976796].
223 Gandhi P, Bustani R, Madhuvrata P, et al. Introduction of metformin for gestational diabetes mellitus in clinical practice: has it had an impact?. Eur J Obstet Gynecol Reprod Biol. 2012;160(2):147-50. [pmid: 22137984].
224 Bahado-Singh RO, Mele L, Landon MB, et al. Fetal male gender and the benefits of treatment of mild gestational diabetes mellitus. Am J Obstet Gynecol. 2012;206(5):422-5. [pmid: 22542118].
225 Dennedy MC, Avalos G, O'Reilly MW, et al. ATLANTIC-DIP: raised maternal body mass index (BMI) adversely affects maternal and fetal outcomes in glucose-tolerant women according to International Association of Diabetes and Pregnancy Study Groups (IADPSG) criteria. J Clin Endocrinol Metab. 2012;97(4):E608-E612. [pmid: 22319044].
226 Gasim T. Gestational diabetes mellitus: maternal and perinatal outcomes in 220 saudi women. Oman Med J. 2012;27(2):140-4. [pmid: 22496940].
227 O'Dwyer V, Farah N, Hogan J, et al. Timing of screening for gestational diabetes mellitus in women with moderate and severe obesity. Acta Obstet Gynecol Scand. 2012;91(4):447-51. [pmid: 22085417].

## Excluded – Duplicate (N=10)

1 Cabero L, Corcoy R, Cerqueria MJ, Codina M. Treatment and Outcome of 100 Gestational Diabetics. 1989.
2 Retnakaran R. lsolated Hyperglycemia at 1 Hour on Oral Glucose Tolerance Test in Pregnancy Resembles Gestational Diabetes Mellitus in Predicting Postpartum Metabolic Dysfunction. Diabetes Care. 2008;2008(7):1275-81. [pmid: 18356402].
3 Landon MB, Thom E, Spong CY, et al. The National Institute of Child Health and Human Development Maternal-Fetal Medicine Unit Network randomized clinical trial in progress: Standard therapy versus no therapy for mild gestational diabetes. Diabetes Care. 2007;30(Suppl 2):S194-S199. [pmid: 17596471].
4 Landon MB. The national institute of child health and human development maternal-fetal medicine unit network randomized clinical trial in progress : Standard therapy versus no therapy for mild gestational diabetes. Proceedings of the fifth International Workshop-Conference on Gestational Diabetes Mellitus. 11-13 November 2005. Chicago, Illinois. Diabetes Care. 2007;30(Suppl 2):S194-S199.
5 Landon MB, Thom E, Spong CY, Carpenter M, et al. The National Institute of Child Health and Human Development Maternal-Fetal Medicine Unit Network randomized clinical trial in progress: standard therapy versus no therapy for mild gestational diabetes. Chicago, IL. 2007:S194-S199.
6 Langer O, Yogev Y, Most O. Gestational diabetes mellitus: the consequences of not treating. Am J Obstet Gynecol. 2005;192(4):989-997. [pmid: 15846171].
7 Reichelt AJ, Spichler ER, Branchtein L, et al. Easting plasma glucose is a useful test for the detection of gestational diabetes. Diabetes Care. 1998;21(8):1246-9. [pmid: 9702428].
8 Naylor CD, Sermer M, Chen EL, et al. Selective screening for gestational diabetes mellitus. N Engl J Med. 1997;337(22):1591-6. [pmid: 9371855].
9 Balaji V, Balaji MS, Alexander C, et al. Premixed insulin aspart 30 (biasp 30) vs premixed human insulin 30 (bhi 30) in gestational diabetes mellitus - a pilot study. J Assoc Physicians India. 2010;58(2):95-7.
10 Retnakaran R. -Cell Function Declines Within the First Year Postpartum in Women With Recent Glucose Intolerance in Pregnancy. Diabetes Care. 2010;2010(8):1798-804. [pmid: 20484133].

## Excluded – Intervention (N=12)

1 Persily CA. Relationships between the perceived impact of gestational diabetes mellitus and treatment adherence. J Obstet Gynecol Neonatal Nurs. 1996;25(7):601-7.
2 Fisher JE, Smith RS, Lagrandeur R, et al. Gestational diabetes mellitus in women receiving beta-adrenergics and corticosteroids for threatened preterm delivery. Obstet Gynecol. 1997;90(6):880-3. [pmid: 9397094].
3 Moses RG, Lucas EM, Knights S. Gestational diabetes mellitus. At what time should the postprandial glucose level be monitored?. Aust N Z J Obstet Gynaecol. 1999;39(4):457-60. [pmid: 10687763].
4 Nachum Z, Ben-Shlomo I, Weiner E, et al. Twice daily versus four times daily insulin dose regimens for diabetes in pregnancy: randomised controlled trial. BMJ: British Medical Journal (International Edition). 1999;319(7219):1223-7.
5 Holt RI, Goddard JR, Clarke P, et al. A postnatal fasting plasma glucose is useful in determining which women with gestational diabetes should undergo a postnatal oral glucose tolerance test. Diabetic Med. 2003;20(7):594-8. [pmid: 12823243].
6 Mosca A, Paleari R, Dalfra MG, et al. Reference intervals for hemoglobin A1c in pregnant women: data from an Italian multicenter study. Clin Chem. 2006;52(6):1138-43. [pmid: 16601066].
7 Wong ML, Wong WH, Cheung YF. Fal myocardial performance in pregnancies complicated by gestational impaired glucose toleranceet. Ultrasound Obstet Gynecol. 2007;29(4):395-400. [pmid: 17330321].
8 Kakad R, Anwar A, Dyer P, et al. Fasting plasma glucose is not sufficient to detect ongoing glucose intolerance after pregnancy complicated by gestational diabetes. Exp Clin Endocrinol Diabetes. 2010;118(4):234-6. [pmid: 20162508].
9 Halkoaho A, Kavilo M, Pietila AM, et al. Does gestational diabetes affect women's health-related quality of life after delivery?. Eur J Obstet Gynecol Reprod Biol. 2010;148(1):40-3. [pmid: 19883969].
10 Karcaaltincaba D, Buyukkaragoz B, Kandemir O, et al. Gestational diabetes and gestational impaired glucose tolerance in 1653 teenage pregnancies: prevalence, risk factors and pregnancy outcomes. J Pediatr Adolesc Gynecol. 2011;24(2):62-5. [pmid: 20709580].
11 Perera NJ, Molyneaux L, Constantino MI, et al. Suboptimal performance of blood glucose meters in an antenatal diabetes clinic. Diabetes Care. 2011;34(2):335-7. [pmid: 21216849].
12 Catalano PM, McIntyre HD, Cruickshank JK, et al. The hyperglycemia and adverse pregnancy outcome study: associations of GDM and obesity with pregnancy outcomes. Diabetes Care. 2012;35(4):780-6. [pmid: 22357187].

## Excluded – Key Question 1 RCS (N=54)

1 Swinn RA, Wareham NJ, Gregory R, et al. Excessive secretion of insulin precursors characterizes and predicts gestational diabetes. Diabetes. 1995;44(8):911-5. [pmid: 7621996].
2 Hooper DE. Detecting GD and preeclampsia. Effectiveness of routine urine screening for glucose and protein. J Reprod Med. 1996;41(12):885-8. [pmid: 8979200].
3 Landy HJ, Gomez-Marin O, O'Sullivan MJ. Diagnosing gestational diabetes mellitus: use of a glucose screen without administering the glucose tolerance test. Obstet Gynecol. 1996;87(3):395-400. [pmid: 8598962].
4 Tan YY, Yeo GS. Impaired glucose tolerance in pregnancy--is it of consequence?. Aust N Z J Obstet Gynaecol. 1996;36(3):248-55. [pmid: 8883744].
5 Kousta E, Lawrence NJ, Penny A, et al. Implications of new diagnostic criteria for abnormal glucose homeostasis in women with previous gestational diabetes. Diabetes Care. 1999;22(6):933-7. [pmid: 10372245].
6 Atilano LC, Lee-Parritz A, Lieberman E, et al. Alternative methods of diagnosing gestational diabetes mellitus. Am J Obstet Gynecol. 1999;181(5 Pt 1):1158-61. [pmid: 10561637].
7 Khine ML, Winklestein A, Copel JA. Selective screening for gestational diabetes mellitus in adolescent pregnancies. Obstet Gynecol. 1999;93(5 Pt 1):738-42. [pmid: 10912977].
8 Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-del-Castillo JD, et al. Predictive value of a screen for gestational diabetes mellitus: influence of associated risk factors. Acta Obstet Gynecol Scand. 2000;79(11):991-8. [pmid: 11081686].
9 Grover J, Beall MH, Ross MG. Intrapartum screen for diabetes in patients without prenatal care: use of labor admission serum glucose. J Matern Fetal Med. 2000;9(4):216-8. [pmid: 11048831].
10 Shamsuddin K, Mahdy ZA, Siti RI, et al. Risk factor screening for abnormal glucose tolerance in pregnancy. Int J Gynaecol Obstet. 2001;75(1):27-32. [pmid: 11597616].
11 Kyle CV, Cundy TF. Screening for gestational diabetes mellitus: can we be more efficient?. Aust N Z J Obstet Gynaecol. 2001;41(3):285-90. [pmid: 11592542].
12 Chan LY, Wong SF, Ho LC. Diabetic family history is an isolated risk factor for gestational diabetes after 30 years of age. Acta Obstet Gynecol Scand. 2002;81(2):115-7. [pmid: 11942900].
13 Larijani B, Hossein-nezhad A, Rizvi SW, et al. Cost analysis of different screening strategies for gestational diabetes mellitus. Endocrine Pract. 2003;9(6):504-9.
14 Miyakoshi K, Tanaka M, Ueno K, et al. Cutoff value of 1 h, 50 g glucose challenge test for screening of gestational diabetes mellitus in a Japanese population. Diabetes Res Clin Pract. 2003;60(1):63-7. [pmid: 12639767].
15 De Sereday MS, Damiano MM, Gonzalez CD, et al. Diagnostic criteria for gestational diabetes in relation to pregnancy outcome. J Diabetes Complications. 2003;17(3):115-9. [pmid: 12738394].
16 Schytte T, Jorgensen LG, Brandslund I, et al. The clinical impact of screening for gestational diabetes. Clin Chem Lab Med. 2004;42(9):1036-42. [pmid: 15497470].
17 Jakobi P, Solt I, Weissman A. A 2 hour versus the 3 hour 100 g glucose tolerance test for diagnosing gestational diabetes mellitus. J Perinat Med. 2004;32(4):320-2. [pmid: 15346816].
18 Caliskan E, Kayikcioglu F, Ozturk N, et al. A population-based risk factor scoring will decrease unnecessary testing for the diagnosis of gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2004;83(6):524-30. [pmid: 15144332].
19 Sun JH, See LC, Chiu TH, et al. An appropriate indicator for diagnosing gestational diabetes. Chang Gung Medical Journal. 2005;28(12):824-8. [pmid: 16515015].
20 Agarwal MM, Dhatt GS, Punnose J, et al. Gestational diabetes: dilemma caused by multiple international diagnostic criteria. Diabetic Med. 2005;22(12):1731-6. [pmid: 16401320].
21 Esakoff TF, Cheng YW, Caughey AB. Screening for gestational diabetes: different cut-offs for different ethnicities?. Am J Obstet Gynecol. 2005;193(3 Suppl):1040-4. [pmid: 16157108].
22 Dabelea D, Snell-Bergeon JK, Hartsfield CL, et al. Increasing prevalence of gestational diabetes mellitus (GDM) over time and by birth cohort: Kaiser Permanente of Colorado GDM Screening Program. Diabetes Care. 2005;28(3):579-84. [pmid: 15735191].
23 Cheng YW, Esakoff TF, Block-Kurbisch I, et al. Screening or diagnostic: markedly elevated glucose loading test and perinatal outcomes. J Matern Fetal Neonatal Med. 2006;19(11):729-34. [pmid: 17127496].
24 Rodacki M, Lacativa PG, Lima GA, et al. Can we simplify the 100-g oral glucose tolerance test in pregnancy?. Diabetes Res Clin Pract. 2006;71(3):247-50. [pmid: 16171887].
25 Agarwal MM, Dhatt GS, Punnose J. Gestational diabetes: an alternative, patient-friendly approach for using the diagnostic 100-g OGTT in high-risk populations. Arch Gynecol Obstet. 2006;273(6):325-30. [pmid: 16328394].
26 Fadl H, Ostlund I, Nilsson K, et al. Fasting capillary glucose as a screening test for gestational diabetes mellitus. BJOG. 2006;113(9):1067-71. [pmid: 16956338].
27 Johnston-MacAnanny EB, Ness A, Weinstein L. Diagnosis of gestational diabetes mellitus: is it time for a new critical value?. J Reprod Med. 2007;52(6):463-6. [pmid: 17694961].
28 Hackmon R, James R, O'Reilly GC, et al. The impact of maternal age, body mass index and maternal weight gain on the glucose challenge test in pregnancy. J Matern Fetal Neonatal Med. 2007;20(3):253-7. [pmid: 17437228].
29 Khan HA, Sobki SH, Alhomida AS, et al. Indian J Clin Biochem. 2007;22(1):65-70. [pmid: 23105655].
30 Ogonowski J, Miazgowski T, Homa K, et al. Low predictive value of traditional risk factors in identifying women at risk for gestational diabetes. Acta Obstet Gynecol Scand. 2007;86(10):1165-70. [pmid: 17851799].
31 Rudge MV, Lima CA, Paulette TA, et al. Influence of lower cutoff values for 100-g oral glucose tolerance test and glycemic profile for identification of pregnant women at excessive fetal growth risk. Endocrine Pract. 2008;14(6):678-85.
32 Yamasmit W, Chaithongwongwatthana S, Uerpairojkit B. A 50-g glucose challenge test: is there any diagnostic cut-off?. J Med Assoc Thai. 2008;91(9):1309-12. [pmid: 18843856].
33 Punthumapol C, Tekasakul P. 50 grams glucose challenge test for screening of gestational diabetes mellitus in each trimester in potential diabetic pregnancy. J Med Assoc Thai. 2008;91(6):787-93. [pmid: 18697374].
34 Montagnana M, Lippi G, Targher G, et al. Glucose challenge test does not predict gestational diabetes mellitus. Intern Med. 2008;47(13):1171-4. [pmid: 18591836].
35 Korucuoglu U, Biri A, Turkyilmaz E, et al. Glycemic levels with glucose loading test during pregnancy and its association with maternal and perinatal outcomes. Diabetes Res Clin Pract. 2008;80(1):69-74. [pmid: 18067985].
36 Boriboonhirunsarn D, Sunsaneevithayakul P. Abnormal results on a second testing and risk of gestational diabetes in women with normal baseline glucose levels. Int J Gynaecol Obstet. 2008;100(2):147-53. [pmid: 18005964].
37 Phaloprakarn C, Tangjitgamol S. Diagnosis of gestational diabetes mellitus using a modified 100 g oral glucose tolerance test. J Perinatol. 2008;28(1):7-11. [pmid: 18165827].
38 Aldasouqi SA, Solomon DJ, Bokhari SA, et al. Glycohemoglobin A1c: A promising screening tool in gestational diabetes mellitus. Int J Diabetes Dev Ctries. 2008;28(4):121-4. [pmid: 20165599].
39 Phaloprakarn C, Tangjitgamol S, Manusirivithaya S. A risk score for selective screening for gestational diabetes mellitus. Eur J Obstet Gynecol Reprod Biol. 2009;145(1):71-5. [pmid: 19446948].
40 Wong VW, Garden F, Jalaludin B. Hyperglycaemia following glucose challenge test during pregnancy: When can a screening test become diagnostic?. Diabetes Res Clin Pract. 2009;83(3):394-6. [pmid: 19124172].
41 Karcaaltincaba D, Kandemir O, Yalvac S, et al. Prevalence of gestational diabetes mellitus and gestational impaired glucose tolerance in pregnant women evaluated by National Diabetes Data Group and Carpenter and Coustan criteria. Int J Gynaecol Obstet. 2009;106(3):246-9. [pmid: 19464683].
42 Flack JR, Ross GP, Ho S, et al. Recommended changes to diagnostic criteria for gestational diabetes: impact on workload. Aust N Z J Obstet Gynaecol. 2010;50(5):439-43. [pmid: 21039377].
43 Ruangvutilert P, Chaemsaithong P, Ruangrongmorakot K, et al. Development of a modified 100-gram oral glucose tolerance test for diagnosis of gestational diabetes mellitus and its diagnostic accuracy. J Med Assoc Thai. 2010;93(10):1121-7. [pmid: 20973313].
44 Kalamegham R, Nuwayhid BS, Mulla ZD. Prevalence of gestational fasting and postload single dysglycemia in Mexican-American women and their relative significance in identifying carbohydrate intolerance. Am J Perinatol. 2010;27(9):697-704. [pmid: 20387187].
45 Agarwal MM, Dhatt GS, Shah SM. Gestational Diabetes Mellitus Simplifying the International Association of Diabetes and Pregnancy diagnostic algorithm using fasting plasma glucose. Diabetes Care. 2010;33(9):2018-20. [pmid: 20519664].
46 Hansarikit J, Manotaya S. Sensitivity and specificity of modified 100-g oral glucose tolerance tests for diagnosis of gestational diabetes mellitus. J Med Assoc Thai. 2011;94(5):540-4. [pmid: 21675441].
47 Teh WT, Teede HJ, Paul E, et al. Risk factors for gestational diabetes mellitus: implications for the application of screening guidelines. Aust N Z J Obstet Gynaecol. 2011;51(1):26-30. [pmid: 21299505].
48 Shah A, Stotland NE, Cheng YW, et al. The association between body mass index and gestational diabetes mellitus varies by race/ethnicity. Am J Perinatol. 2011;28(7):515-20. [pmid: 21404165].
49 Samuel A, Simhan HN. Clinical indications for abnormal early gestational 50-g glucose tolerance testing. Am J Perinatol. 2011;28(6):485-7. [pmid: 21225558].
50 Huynh J, Ratnaike S, Bartalotta C, et al. Challenging the glucose challenge test. Aust N Z J Obstet Gynaecol. 2011;51(1):22-5. [pmid: 21299504].
51 Church D, Halsall D, Meek C, et al. Random Blood Glucose Measurement at Antenatal Booking to Screen for Overt Diabetes in Pregnancy: A retrospective study. Diabetes Care. 2011;34(10):2217-9. [pmid: 21844290].
52 Gandhi P, Farrell T. Gestational diabetes mellitus (GDM) screening in morbidly obese pregnant women. Eur J Obstet Gynecol Reprod Biol. 2011;159(2):329-32. [pmid: 21968030].
53 Kosus A, Kosus N, Turhan NO. Gestational diabetes: comparision of the carpenter and the coustan thresholds with the new thresholds of turkish women and implications of variations in diagnostic criteria. J Matern Fetal Neonatal Med. 2011.
54 Teede HJ, Harrison CL, Teh WT, et al. Gestational diabetes: Development of an early risk prediction tool to facilitate opportunities for prevention. Aust N Z J Obstet Gynaecol. 2011;51(6):499-504. [pmid: 21951203].

## Excluded – Outcome (N=34)

1 Tan YY, Liauw PC, Yeo GS. Using glucose tolerance test results to predict insulin requirement in women with gestational diabetes. Aust N Z J Obstet Gynaecol. 1995;35(3):262-6. [pmid: 8546639].
2 Phillipov G. Short- and long-term reproducibility of the 1-h 50-g glucose challenge test. Clin Chem. 1996;42(2):255-7. [pmid: 8595720].
3 Giampietro O, Matteucci E. Gestational diabetes mellitus (GDM) and macrosomia: a controversial story. Ann Ist Super Sanita. 1997;33(3):399-402. [pmid: 9542270].
4 Kerbel D, Glazier R, Holzapfel S, et al. Adverse effects of screening for gestational diabetes: a prospective cohort study in Toronto, Canada. J Med Screen. 1997;4(3):128-32. [pmid: 9368868].
5 Weiss PAM. Toward universal criteria for gestational diabetes : Relationships between seventy-five and one hundred gram glucose loads and between capillary and venous glucose concentrations. Am J Obstet Gynecol. 1998;1998(4):835.
6 Mills JL, Jovanovic L, Knopp R, et al. Physiological reduction in fasting plasma glucose concentration in the first trimester of normal pregnancy: the diabetes in early pregnancy study. Metabolism. 1998;47(9):1140-4. [pmid: 9751245].
7 Stulberg RA, John SL, Houlden RL. Gestational age at screening, diagnosis and management of gestational diabetes in a Canadian community. Canadian Journal of Diabetes. 1999;23(3):27-31.
8 Griffin ME, Coffey M, Johnson H, et al. Universal vs. risk factor-based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabetic Med. 2000;17(1):26-32. [pmid: 10691156].
9 Juutinen J, Hartikainen AL, Bloigu R, et al. A retrospective study on 435 women with gestational diabetes: Fasting plasma glucose is not sensitive enough for screening but predicts a need for insulin treatment [7]. Diabetes Care. 2000;23(12):1858-9. [pmid: 11128372].
10 Weiss PA, Haeusler M, Tamussino K, et al. Can glucose tolerance test predict fetal hyperinsulinism?. BJOG. 2000;107(12):1480-5. [pmid: 11192103].
11 Zargar AH, Khan AK, Masoodi SR, et al. Prevalence of type 2 diabetes mellitus and impaired glucose tolerance in the Kashmir Valley of the Indian subcontinent. Diabetes Res Clin Pract. 2000;47(2):135-46. [pmid: 10670914].
12 Kirwan JP, Huston-Presley L, Kalhan SC, et al. Clinically useful estimates of insulin sensitivity during pregnancy: validation studies in women with normal glucose tolerance and gestational diabetes mellitus. Diabetes Care. 2001;24(9):1602-7. [pmid: 11522706].
13 Davey RX, Hamblin PS. Selective versus universal screening for gestational diabetes mellitus: an evaluation of predictive risk factors. Med J Aust. 2001;174(3):118-21. [pmid: 11247613].
14 Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-del-Castillo JD, et al. Prevalence of gestational diabetes mellitus: variations related to screening strategy used. Eur J Endocrinol. 2002;146(6):831-7. [pmid: 12039704].
15 Jorgensen LG, Schytte T, Brandslund I, et al. Fasting and post-glucose load--reference limits for peripheral venous plasma glucose concentration in pregnant women. Clin Chem Lab Med. 2003;41(2):187-99. [pmid: 12667006].
16 Roggenbuck LF, Kleinwechter HJ, Demandt N, et al. Diagnostics of gestational diabetes: which cutoff-values are valid for capillary whole blood?. Clin Lab. 2004;50(7-8):403-8. [pmid: 15330507].
17 Bito T, Foldesi I, Nyari T, et al. Prediction of gestational diabetes mellitus in a high-risk group by insulin measurement in early pregnancy. Diabetic Med. 2005;22(10):1434-9. [pmid: 16176208].
18 Bito T, Nyari T, Kovacs L, et al. Oral glucose tolerance testing at gestational weeks < or =16 could predict or exclude subsequent gestational diabetes mellitus during the current pregnancy in high risk group. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):51-5. [pmid: 15989984].
19 Cypryk K, Pertynska-Marczewska M, Szymczak W, et al. Evaluation of metabolic control in women with gestational diabetes mellitus by the continuous glucose monitoring system: a pilot study. Endocrine Pract. 2006;12(3):245-50.
20 Thomas B, Ghebremeskel K, Lowy C, et al. Nutrient intake of women with and without gestational diabetes with a specific focus on fatty acids. Nutrition. 2006;22(3):230-6. [pmid: 16500549].
21 Seshiah V, Balaji V, Balaji MS, et al. Glycemic level at the first visit and prediction of GDM. J Assoc Physicians India. 2007;55:630-2. [pmid: 18051734].
22 van LM, Opmeer BC, Zweers EJ, et al. Estimating the risk of gestational diabetes mellitus: a clinical prediction model based on patient characteristics and medical history. BJOG. 2010;117(1):69-75. [pmid: 20002371].
23 Zisser HC, Biersmith MA, Jovanovic LB, et al. Fetal risk assessment in pregnancies complicated by diabetes mellitus. J Diabetes Sci Technol. 2010;4(6):1368-73. [pmid: 21129331].
24 Luo ZC, Delvin E, Fraser WD, et al. Maternal glucose tolerance in pregnancy affects fetal insulin sensitivity. Diabetes Care. 2010;33(9):2055-61. [pmid: 20573751].
25 Akinci B, Celtik A, Yener S, et al. Prediction of developing metabolic syndrome after gestational diabetes mellitus. Fertil Steril. 2010;93(4):1248-54. [pmid: 19147138].
26 Radaelli T, Farrell KA, Huston-Presley L, et al. Estimates of insulin sensitivity using glucose and C-Peptide from the hyperglycemia and adverse pregnancy outcome glucose tolerance test. Diabetes Care. 2010;33(3):490-4. [pmid: 20032280].
27 Meltzer SJ, Snyder J, Penrod JR, et al. Gestational diabetes mellitus screening and diagnosis: a prospective randomised controlled trial comparing costs of one-step and two-step methods. BJOG. 2010;117(4):407-15. [pmid: 20105163].
28 Das S, Behera MK, Misra S, et al. Beta-cell function and insulin resistance in pregnancy and their relation to fetal development. Metab Syndr Relat Disord. 2010;8(1):25-32. [pmid: 19929599].
29 Lopez Caudana AE, Lopez RR, Gonzalez VC, et al. Prediction of alterations in glucose metabolism by glucose and insulin measurements in early pregnancy. Arch Med Res. 2011;42(1):70-6. [pmid: 21376266].
30 Perovic M, Garalejic E, Gojnic M, et al. Sensitivity and specificity of ultrasonography as a screening tool for gestational diabetes mellitus. J Matern Fetal Neonatal Med. 2011.
31 Wendland EM, Duncan BB, Mengue SS, et al. Lesser than diabetes hyperglycemia in pregnancy is related to perinatal mortality: a cohort study in Brazil. BMC Pregnancy Childbirth. 2011;11:92. [pmid: 22078268].
32 Gibson KS, Waters TP, Catalano PM. Maternal weight gain in women who develop gestational diabetes mellitus. Obstet Gynecol. 2012;119(3):560-5. [pmid: 22353954].
33 Verhaeghe J, Van HE, Benhalima K, et al. Glycated hemoglobin in pregnancies at increased risk for gestational diabetes mellitus. Eur J Obstet Gynecol Reprod Biol. 2012;161(2):157-62. [pmid: 22342592].
34 Werner EF, Pettker CM, Zuckerwise L, et al. Screening for gestational diabetes mellitus: are the criteria proposed by the international association of the Diabetes and Pregnancy Study Groups cost-effective?. Diabetes Care. 2012;35(3):529-35. [pmid: 22266735].

## Excluded – Population (N=15)

1 Gribble RK, Fee SC, Berg RL. The value of routine urine dipstick screening for protein at each prenatal visit. Am J Obstet Gynecol. 1995;173(1):214-7. [pmid: 7631685].
2 Chang CJ, Wu JS, Lu FH, et al. Fasting plasma glucose in screening for diabetes in the Taiwanese population. Diabetes Care. 1998;21(11):1856-60. [pmid: 9802733].
3 Bor MV, Bor P, Cevik C. Serum fructosamine and fructosamine-albumin ratio as screening tests for gestational diabetes mellitus. Arch Gynecol Obstet. 1999;262(3-4):105-11. [pmid: 10326628].
4 Rich-Edwards JW, Colditz GA, Stampfer MJ, et al. Birthweight and the risk for type 2 diabetes mellitus in adult women. Ann Intern Med. 1999;130(4 Pt 1):278-84. [pmid: 10068385].
5 Gray-Donald K, Robinson E, Collier A, et al. Intervening to reduce weight gain in pregnancy and gestational diabetes mellitus in Cree communities: an evaluation. CMAJ (Ottawa). 2000;163(10):1247-51.
6 Ko GT, Chan JC, Tsang LW, et al. Combined use of fasting plasma glucose and HbA1c predicts the progression to diabetes in Chinese subjects. Diabetes Care. 2000;23(12):1770-3. [pmid: 11128350].
7 Agarwal MM, Punnose J, Dhatt GS. Gestational diabetes: Implications of variation in post-partum follow-up criteria. Eur J Obstet Gynecol Reprod Biol. 2004;113(2):149-53. [pmid: 15063951].
8 Akhlaghi F, Hamedi AB. Comparison of maternal and fetal/neonatal complications in gestational and pre-gestational diabetes mellitus. Acta Medica Iranica. 2005;43(4):263-7.
9 Sandbaek A, Lauritzen T, Borch-Johnsen K, et al. The comparison of venous plasma glucose and whole blood capillary glucose in diagnoses of Type 2 diabetes: a population-based screening study. Diabet Med. 2005;22(9):1173-7. [pmid: 16108845].
10 Kraemer J, Klein J, Lubetsky A, et al. Perfusion studies of glyburide transfer across the human placenta: implications for fetal safety. Am J Obstet Gynecol. 2006;195(1):270-4. [pmid: 16579925].
11 Franks PW, Looker HC, Kobes S, et al. Gestational glucose tolerance and risk of type 2 diabetes in young Pima Indian offspring. Diabetes. 2006;55(2):460-5. [pmid: 16443781].
12 Ratner RE, Christophi CA, Metzger BE, et al. Prevention of diabetes in women with a history of gestational diabetes: effects of metformin and lifestyle interventions. J Clin Endocrinol Metab. 2008;93(12):4774-9. [pmid: 18826999].
13 Phillips LS, Ziemer DC, Kolm P, et al. Glucose challenge test screening for prediabetes and undiagnosed diabetes. Diabetologia. 2009;52(9):1798-807. [pmid: 19557386].
14 Opara PI, Jaja T, Onubogu UC. Morbidity and mortality amongst infants of diabetic mothers admitted into a special care baby unit in Port Harcourt, Nigeria. Ital J Pediatr. 2010;36(1):77. [pmid: 21138582].
15 Ohno MS, Sparks TN, Cheng YW, et al. Treating mild gestational diabetes mellitus: a cost-effectiveness analysis. Am J Obstet Gynecol. 2011;205(3):282-e1-7. [pmid: 22071065].

## Excluded – Publication Type (N=106)

1 Joshi R, Bharadwaj A. Gestational diabetes screening: can hemoglobin A∼1∼C measurement replace the glucose challenge test?. Obstet Gynecol. 2002;99(4 Suppl 1):S93.
2 Forest JC, Masse J, Garrido-Russo M. Glucose tolerance test during pregnancy: the significance of one abnormal value. Clin Biochem. 1994;27(4):299-304. [pmid: 8001292].
3 JovanovicPeterson L, Bevier W, Peterson CM. A Cost-Effective Program to Normalize Birth-Weight (Bwt) by Screening for and Treatment of Glucose-Intolerance of Pregnancy (Igt). Diabetes. 1995;44:A258.
4 Dolci M, Bianchini G, Andreani G, et al. Screening and treatment of gestational diabetes (GDM): The experience of seven years. Diabetologia. 1996;39(Suppl 1):769.
5 Pavlic Renar I, Tomic M, Horvat B, Metelko Z. Screening and intervention in gestational diabetes mellitus. Fourth meeting for the implementation of the St. Vincent declaration. Lisbon. 1997:55.
6 Roncaglia N, Arreghini A, Bellini P, Bertalero C, et al. Gestational diabetes mellitus: is therapy always necessary?. Rome. 1997:68.
7 Harder T, Plagemann A, Kohlhoff R, Rohde W. Overweight and obesity in children of mothers with long-term insulin-dependent diabetes or gestational diabetes. 1997.
8 Cypryk K, Wilczynski J, Penza G, Krekora M. Early detection of gestational diabetes (GDM) improves pregnancy outcome. 1997.
9 Bancroft K, Tuffnell DJ, Mason GC, et al. A randomized controlled study of the management of impaired glucose intolerance in pregnancy. Br J Obstet Gynaecol. 1998;105(Suppl 17):53-4. [pmid: 9442162].
10 Pavlic Renar I, Tomic M, Horvat B, Metelko Z. Screening and intervention in gestational diabetes mellitus. 1998.
11 Persson B, Hanson U. Neonatal morbidities in gestational diabetes mellitus. Diabetes Care. Suppl 2. 1998;21:B79-B84. [pmid: 9704232].
12 Jovanovic L. Optimization of insulin therapy in patients with gestational diabetes. Endocrine Pract. 2000;6(1):98-100.
13 Hadden D. Evidence-based screening for gestational diabetes?. Diabetic Med. 2000;17(5):402-4. [pmid: 10872544].
14 Kitzmiller JL. Cost analysis of diagnosis and treatment of gestational diabetes mellitus. Clin Obstet Gynecol. 2000;43(1):140-53. [pmid: 10694996].
15 Souvatzoglou ES, Anastasiou E, Alevizaki M, et al. Is there any cutoff point of HbA1c levels indicative of the need for insulin treatment in women with gestational diabetes?. Diabetologia. 2001;44(Suppl 1):A42.
16 de Aguiar LG, de Matos HJ, de Brito GM. Could fasting plasma glucose be used for screening high-risk outpatients for gestational diabetes mellitus?. Diabetes Care. 2001;24(5):954-5. [pmid: 11347763].
17 Berger H, Crane J, Farine D, et al. Screening for gestational diabetes mellitus. J Obstet Gynaecol Can. 2002;24(11):894-912. [pmid: 12417905].
18 McElduff A, Hitchman R. Screening for gestational diabetes: The time of day is important. The Medical Journal Of Australia. 2002;176(3):136. [pmid: 11936316].
19 Bustani RJ, Todd DM, Akinsola M, et al. Increased insulin usage and reduced macrosomia in gestational diabetes mellitus managed with post-prandial blood glucose targets. Diabetologia. 2002;45(Suppl 2):A291.
20 Jang HC, Park B, Park J, et al. Carbohydrate restricted diet in Korean women with mild gestational diabetes mellitus. Diabetes. 2002;51:A615.
21 Castracane VD, Myles TD, Driggs SC, White D, et al. Early Detection of Gestational Diabetes is Enhances With Glucose Tolerance Testing in Early Pregnancy Source. Los Angeles, CA. 2002:171A.
22 Seshiah V, Balaji V, Balaji MS. Diagnosis and management of diabetes in pregnancy. J Indian Med Assoc. 2003;101(12):742. [pmid: 15198403].
23 Giuffrida FM, Castro AA, Atallah AN, et al. Diet plus insulin compared to diet alone in the treatment of gestational diabetes mellitus: a systematic review. Braz J Med Biol Res. 2003;36(10):1297-300. [pmid: 14502360].
24 McElduff A. Shared care: gestational diabetes. Aust Fam Physician. 2003;32(3):113-7. [pmid: 12666347].
25 Platt J, O'Brien W. Acarbose therapy for gestational diabetes: A retrospective cohort study. Am J Obstet Gynecol. 2003;189(6):S107.
26 Yogev Y, Langer O, Rosenn B, et al. Glucose challenge test as a predictor for gestational diabetes in mexican american women. Am J Obstet Gynecol. 2003;189(6 Suppl):S86.
27 Senanayake H, Ariyaratne H, Wijeratne S. Is there a place for a single value oral glucose tolerance test for the diagnosis of gestational diabetes mellitus?. Ceylon Med J. 2004;49(4):136. [pmid: 15693456].
28 Fotinos C, Dodson S. Does tight control of blood glucose in pregnant women with diabetes improve neonatal outcomes?. J Fam Pract. 2004;53(10):838-40. [pmid: 15469784].
29 Arnqvist HJ, Hanson U, Nystrom L, et al. A population based study (G-DISS) of diagnosis of gestational diabetes and pregnancy outcome. Importance of fasting blood glucose. Diabetologia. 2004;47(Suppl 1):A351.
30 Cheung NW, Oats JJ, McIntyre HD. Australian carbohydrate intolerance study in pregnant women: implications for the management of gestational diabetes. Aust N Z J Obstet Gynaecol. 2005;45(6):484-5. [pmid: 16401212].
31 Yang HX, Gao XL, Dong Y, et al. Analysis of oral glucose tolerance test in pregnant women with abnormal glucose metabolism. Chin Med J. 2005;118(12):995-9. [pmid: 15978207].
32 Hawkins JS, Lo J, Casey B, et al. Pregnancy outcomes associated with early diagnosis of diet-treated gestational diabetes. Am J Obstet Gynecol. 2005;193(6):S91.
33 Moore L, Clokey D, Robinson A. A randomized trial of metformin compared to glyburide in the treatment of gestational diabetes. Am J Obstet Gynecol. 2005;193(6):S92.
34 Ramos G, Jacobson G, Kirby R, et al. Comparison of glyburide and insulin for the management of gestational diabetics with greatly elevated oral glucose challenge test and fasting hyperglycemia. Am J Obstet Gynecol. 2005;193(6):S93.
35 Barbour LA, Kahn BF, Davies JK, et al. Effectiveness of glyburide as an alternative to treat gestational diabetes. Diabetes. 2005;54:A672.
36 Ross G. Gestational diabetes. Aust Fam Physician. 2006;35(6):392-6. [pmid: 16751853].
37 Seely EW. Does treatment of gestational diabetes mellitus affect pregnancy outcome?. Nat Clin Pract Endocrinol Metab. 2006;2(2):72-3. [pmid: 16932258].
38 Loomis L, Lee J, Tweed E. What is appropriate fetal surveillance for women with diet-controlled gestational diabetes?. J Fam Pract. 2006;55(3):238-40. [pmid: 16510059].
39 Chollet MB, Pettitt DJ. Treatment of gestational diabetes mellitus. Clin Diabetes. 2006;24(1):35-6.
40 Simmons D, Wolmarans L, Cutchie W, et al. Gestational diabetes mellitus: Time for consensus on screening and diagnosis. N Z Med J. 2006;119(1228).
41 Cortez J, Tarsa M, Agent S, et al. Randomized controlled trial of acarbose vs. placebo in the treatment of gestational diabetes [abstract]. Am J Obstet Gynecol. 2006;195(6 Suppl 1):S149.
42 Kwik M, Seeho S, Morris J, et al. ACHOIS confirmed: Adverse perinatal outcomes in pregnancies complicated by mild untreated gestational diabetes. Diabetes. 2006;55:A418.
43 Parikh RM, Joshi SR, Menon PS, et al. Intensive glycemic control in diabetic pregnancy with intrauterine growth restriction is detrimental to fetus. Med Hypotheses. 2007;69(1):203-5. [pmid: 17141966].
44 Moss JR, Crowther CA, Hiller JE, et al. Costs and consequences of treatment of gestational diabetes mellitus - evaluation from the ACHOIS randomised trial. Journal of Paediatr Child Health. 2007;43(Suppl 1):A28-A29.
45 Williams M, Nguyen H, Towner D. Use of the maternal serum screen to predict adverse maternal outcomes among pregnant diabetics. Am J Obstet Gynecol. 2007;197(6):S158.
46 De Mendonca NIM, Brace-Well-Milnes TJJ, Kaushal R, et al. Gestational diabetes in a multiethnic London population; the demographics, treatment requirements and pregnancy outcomes and the implications of the ACHOIS trial for them. Diabetologia. 2007;50(Suppl 1):S387.
47 Lundberg GD. Metformin Trumps insulin in the treatment of gestational diabetes. Medscape J Med. 2008;10(7):179. [pmid: 18769686].
48 Rowan JA, Hague WM, Gao W, et al. Metformin versus insulin for the treatment of gestational diabetes. Obstet Gynecol Surv. 2008;63(10):616-8.
49 Tieu J, Crowther CA, Middleton P, et al. Screening for gestational diabetes mellitus for improving maternal and infant health. Cochrane Database of Systematic Reviews. 2008;(3):CD007222.
50 Simmons D. Diagnosis of gestational diabetes mellitus - A comparison of two screening tests. Which is the way ahead?. Nat Clin Pract Endocrinol Metab. 2008;4(2):72-3. [pmid: 17998921].
51 Landon MB. A Prospective Multicenter Randomized Treatment Trial of Mild Gestational Diabetes (Gdm). Am J Obstet Gynecol. 2008;199(6):S2.
52 Lee S, Pettker C, Funai E, et al. Is Lowering the Diagnostic Threshold for Gestational Diabetes (Gdm) Cost-Effective? Implications from the Hyperglycemia and Adverse Pregnancy Outcomes (Hapo) Trial. Am J Obstet Gynecol. 2008;199(6):S199.
53 Riskin-Mashiah S, Auslander R. First Trimester Fasting Hyperglycemia and Adverse Pregnancy Outcomes. Am J Obstet Gynecol. 2008;199(6):S206.
54 Khurana R, Kozak SE, Thompson DM. Which values of the 3 hour 100g oral glucose tolerance test (OGTT) predict who will require insulin for treatment of gestational diabetes (GDM)?. Diabetes. 2008;57:A755.
55 Cheng YW, Block-Kurbisch I, Lydell J, et al. A Different Diagnostic Strategy Using the 100gram, 3-Hour Glucose Tolerance Test for the Diagnosis of Gestational Diabetes Mellitus. Reprod Sci. 2008;15(1 Suppl):245A.
56 Wilson N, Goodwin W, Thomas S, et al. The multidisciplinary diabetes-endocrinology clinic and postprandial blood glucose monitoring in the management of gestational diabetes: Impact on maternal and neonatal outcomes. Diabetic Med. 2009;26:181.
57 Nayyar V, Tier A, Hooker J, et al. Pregnancy outcomes inpatients with gestational diabetes. Diabetic Med. 2009;26:179.
58 Mansell A, Gouveia C, Braggins F, et al. Early screening for gestational diabetes is essential to detect undiagnosed impaired glucose tolerance and Type 2 diabetes in a high risk, ethnically-diverse population. Diabetic Med. 2009;26:117-8.
59 Fontaine P, Schaller S, Lenne X, et al. Increasing incidence of abnormal glucose tolerance in women with gestational diabetes (GDM) or mild gestational diabetes (MGH) in France: DIAGEST 2 study. Diabetologia. 2009;52(Suppl 1):S457.
60 Vambergue A, Schaller S, Lenne X, et al. Anthropometric characteristics at 11 years in children exposed to maternal gestational diabetes mellitus or mild gestational hyperglycaemia in France: DIAGEST 2 study. Diabetologia. 2009;52(Suppl 1):S64.
61 Yakubovich N, Qi Y, Sermer M, et al. Screening glucose challenge test in pregnancy: Impact of family history of diabetes on the likelihood of a false-negative result. Canadian Journal of Diabetes. 2009;33(3):221.
62 Strevens H, Ursing D, Landin-Olsson M. Safe and efficient reporting of blood glucose values during pregnancy. Int J Gynecol Obstet. 2009;107(Suppl 2):S644.
63 Divakar H, Kumar N, Manyonda I. Diagnostic criteria influence prevalence rates for gestational diabetes: Implications for interventions in an Indian pregnant population. Int J Gynecol Obstet. 2009;107(Suppl 2):S439.
64 Phylos B, Lindow S, Coetzee E. Reproducibility of 75 g oral glucose tolerance test in pregnancy in South African population. Int J Gynecol Obstet. 2009;107(Suppl 2):S436-S437.
65 Ng JM, Masson EA, Allan BJ, et al. Post-natal follow up of patients with gestational diabetes: One year onward. Pract Diabetes Int. 2009;26(3):98.
66 Durnwald C. Glycemic characteristics of women treated for mild gestational diabetes and perinatal outcomes. Am J Obstet Gynecol. 2009;201(6):S107.
67 Al-Haddabi R, Scott H, O'connell C, et al. Screening for gestational diabetes: does a false positive glucose challenge test predict adverse pregnancy outcome?. Am J Obstet Gynecol. 2009;201(6):S110.
68 Yogev Y, Chen R, Hod M, et al. Associations with preeclampsia: lessons from the hyperglycemia and adverse pregnancy outcome (HAPO) study. Am J Obstet Gynecol. 2009;201(6):S27.
69 Gillman MW, Oakey H, Baghurst P, et al. Effect of Treatment of Gestational Diabetes on Obesity in the Next Generation. Obesity. 2009;17:S315.
70 Negrato CA, Teixeira MF, Silva CA, et al. Use of Insulin Glargine vs NPH vs Diet in Pregnant Women with Gestational Diabetes. Diabetes. 2009;58:A641.
71 Kohzuma T, Koga M. Lucica GA-L glycated albumin assay kit: a new diagnostic test for diabetes mellitus. Mol Diagn Ther. 2010;14(1):49-51. [pmid: 20121290].
72 Zera CA, Seely EW. Diabetes: Treatment of gestational diabetes reduces obstetric morbidity. Nat Rev Endocrinol. 2010;6(2):69-70. [pmid: 20098447].
73 Rowan JA. Gestational diabetes-complications, management, outcomes. Reprod Fertil Dev. 2010;22:7.
74 Mahdavian M, Hivert MF, Baillargeon JP, et al. Gestational diabetes mellitus: Simplifying the international association of diabetes and pregnancy diagnostic algorithm using fasting plasma glucose. Diabetes Care. 2010;33(11):e145. [pmid: 20980424].
75 Driul L, Londero A, Citossi A, et al. Neonatal and maternal outcomes by gestational diabetes mellitus and impaired glucose tolerance: A retrospective analysis of our 6-years experience. Arch Gynecol Obstet. 2010;282(Suppl 1):S73.
76 Azriel S, Garcia BA, Camao I, et al. Relationship between perinatal outcomes and thyroid-peroxidase antibodies (TPO) in a cohort of pregnant women with gestational diabetes (GD). Diabetologia. 2010;53:S438.
77 O'Reilly MW, Avalos G, Dennedy MC, et al. ATLANTIC DIP: Persistent postpartum glucose intolerance in women with previous gestational diabetes along the Irish Atlantic seaboard. Diabetologia. 2010;53:S430.
78 Anderberg E, Landin-Olsson M, Kalen J, et al. Prevalence of diabetes mellitus after pregnancy with gestational diabetes mellitus using different cut-off criteria for abnormal glucose tolerance. Diabetologia. 2010;53:S153.
79 Onofriescu M, Nemescu D, Tirnoveanu M, et al. Obstetrical and neonatal outcomes of gestational diabetes mellitus. J Matern Fetal Neonatal Med. 2010;23(S1):562.
80 Marco P, Pastor M, Snchez EC, et al. Positive predictive value of O'Sullivan test in pregnants women and incidence of gestational diabetes in torrecardenas hospital. J Matern Fetal Neonatal Med. 2010;23(S1):469. [pmid: 19895353].
81 Martinez PS, Abdulhaj MM, Andres NP, et al. A randomized study comparing metformin and insulin in the treatment of gestational diabetes mellitus. interim results. J Matern Fetal Neonatal Med. 2010;23(S1):381.
82 Gregorini ME, Pagani G, Moretti P, et al. Treatment and gestational outcome in patients with gestational diabetes mellitus (GDM) in relation to the way of diagnosis. J Matern Fetal Neonatal Med. 2010;23(S1):330. [pmid: 19941443].
83 Jenum AK, Sletner L, Voldner N, et al. The STORK Groruddalen research programme: a population-based cohort study of gestational diabetes, physical activity, and obesity in pregnancy in a multiethnic population. Rationale, methods, study population, and participation rates. SCAND J PUBLIC HEALTH. 2010;38(5 Suppl):60-70. [pmid: 21062840].
84 Comparative evaluation of fasting plasma glucose and one hour 50-g glucose challenge test in screening gestational diabetes mellitus. J Zanjan Univ Med Sci Health Serv. 2010;18(71):1-9.
85 Gayle C, Germain S, Marsh MS, et al. Comparing pregnancy outcomes for intensive versus routine antenatal treatment of gestational diabetes based on a 75gram oral glucose tolerance test 2-hour blood glucose 7.8-8.9mmol/l. Diabetologia. 2010;53(Suppl 1).
86 Napoli A, Festa C, Merola G, et al. Low glycaemic index and hypocaloric diet therapy versus conventional approach in gestational diabetes/one abnormal value in pregnancy, after medical nutritional therapy failure. Diabetologia. 2010;53(Suppl 1).
87 Hadden DR, Metzger BE, Lowe LP, et al. Hyperglycaemia and Adverse Pregnancy Outcome (HAPO) Study: Frequency of gestational diabetes mellitus (GDM) at collaborating centers based on IADPSG consensus panel recommended criteria. Diabetologia. 2010;53(Suppl 1):S9.
88 Metzger BE, Lowe LP, Dyer AR, et al. The Hyperglycemia & Adverse Pregnancy Outcome (HAPO) Study: Associations of Higher Levels of Maternal Glucose and BMI with Macrosomia: An Example of Diabesity. Diabetes. 2010;59:A42.
89 Metzger BE, Lowe LP, Dyer AR, et al. The Hyperglycemia & Adverse Pregnancy Outcome (HAPO) Study: Perinatal Outcome in Pregnancies with GDM and Fasting Plasma Glucose (FPG) <= 4.4 mmol/l. Diabetes. 2010;59:A43.
90 Maher N, Reidy F, Walsh J, et al. Gestational diabetes-early treatment without rescreening: does this affect the incidence of macrosomia?. Ir J Med Sci. 2010;179(Suppl 2):S76-S77.
91 Trivedi N, Wen E, Aguayo J, et al. Impact of Diagnostic Intervals in Gestational Diabetes on Glycemic Control and Pregnancy Outcomes. Reprod Sci. 2010;17(3):208A.
92 Simmons D, McElduff A, McIntyre HD, et al. Gestational Diabetes Mellitus: NICE for the US? A comparison of the American Diabetes Association and the American College of Obstetricians and Gynecologists guidelines with the UK National Institute for Health and Clinical Excellence guidelines. Diabetes Care. 2010;33(1):34-7. [pmid: 19837790].
93 Ayach W, Calderon IM, Rudge MV, et al. Comparison between two gestational diabetes screening tests and the perinatal outcome. [Portuguese]. Rev Bras Ginecol Obstet. 2010;32(5):222-8. [pmid: 21085751].
94 Trivedi N, Aguayo J, Agent S, et al. Gestational diabetes in multiple gestations: incidence and implications of early screening. Reprod Sci. 2011;18(Suppl 3):144A.
95 Ma KK. The obstetrical and neonatal implications of a low value on the glucose screening test. Reprod Sci. 2011;18(Suppl 3):142A.
96 Brass E, Sheeder J, Dugoff L. Is there a benefit to screening adolescents for gestational diabetes. Reprod Sci. 2011;18(Suppl 3):139A.
97 Bertini AM, Silva JC, Narciso DRR, et al. Comparative study between metformin and glibenclamide in the treatment of gestational diabetes mellitus. Diabetes Technol Ther. 2011;13(2).
98 Berggren EK, Boggess KA, Funk MJ, et al. Perinatal outcomes associated with changing diagnostic criteria for gestational diabetes National Diabetes Data Group versus Carpenter-Coustan. Am J Obstet Gynecol. 2011;204(1):S224.
99 Zollinger T, Contreras K, Kominiarek M. Large for gestational age infants and the 3-hour oral glucose tolerance test values in gestational diabetes: Is there a relationship?. Am J Obstet Gynecol. 2011;204(1 Suppl):S111.
100 de VM, Wang J, Ferguson C, et al. How does the degree of hyperglycemia recorded during glucose tolerance testing for gestational diabetes impact perinatal outcome?. Am J Obstet Gynecol. 2011;204(1 Suppl):S109.
101 Lee EJ, Kim YH, Kwon JY, et al. Obstetric outcomes with a false positive 1-hour glucose challenge test. Am J Obstet Gynecol. 2011;204(1 Suppl):S107-S108. [pmid: 21419386].
102 Wen E, Trivedi N, Aguayo J, et al. Early versus routine diagnosis of gestational diabetes mellitus: Comparison of perinatal outcomes and postpartum screening. Am J Obstet Gynecol. 2011;204(1 Suppl):S107. [pmid: 21419386].
103 Centre for Reviews and Dissemination. Screening for gestational diabetes mellitus (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;4.
104 Liu Y, Wang J, Du M. Analysis for gestational diabetes screening of 1 676 pregnant women. [Chinese]. Matern Child Health Care China. 2011;26(19):2921.
105 Gorriz S, Esteve S, Guerrero A. Usefulness of Screening for Gestational Diabetes. Clin Chem Lab Med. 2011;49(Suppl 1):S379.
106 Klebanoff M. Treatment of Gestational Diabetes (Gdm), Weight Gain and Perinatal Outcome - Marginal Structural Model (Msm) Analysis. Am J Epidemiol. 2011;173(11 Suppl):S41.

## Excluded – Study Design (N=11)

1 Mires GJ, Williams FL, Harper V. Screening practices for gestational diabetes mellitus in UK obstetric units. Diabet Med. 1999;16(2):138-41. [pmid: 10229307].
2 Kremer CJ, Duff P. Glyburide for the treatment of gestational diabetes. Am J Obstet Gynecol. 2004;190(5):1438-9. [pmid: 15167862].
3 Tanir HM, Sener T, Gurer H, et al. A ten-year gestational diabetes mellitus cohort at a university clinic of the mid-Anatolian region of Turkey. Clin Exp Obstet Gynecol. 2005;32(4):241-4. [pmid: 16440823].
4 Dunne F. Type 2 diabetes and pregnancy. [Review] [56 refs]. Semin Fetal Neonatal Med. 2005;10(4):333-9. [pmid: 15921969].
5 Ferrara A, Weiss NS, Hedderson MM, et al. Pregnancy plasma glucose levels exceeding the American Diabetes Association thresholds, but below the National Diabetes Data Group thresholds for gestational diabetes mellitus, are related to the risk of neonatal macrosomia, hypoglycaemia and hyperbilirubinaemia. Diabetologia. 2007;50(2):298-306. [pmid: 17103140].
6 Gonzalez-Quintero VH, Istwan NB, Rhea DJ, et al. Antenatal factors predicting subsequent need for insulin treatment in women with gestational diabetes. J Womens Health. 2008;17(7):1183-7.
7 Davenport MH, Mottola MF, McManus R, et al. A walking intervention improves capillary glucose control in women with gestational diabetes mellitus: a pilot study. Appl Physiol Nutr Metab. 2008;33(3):511-7. [pmid: 18461104].
8 Son GH, Kwon JY, Kim YH, et al. Maternal serum triglycerides as predictive factors for large-for-gestational age newborns in women with gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2010;89(5):700-4. [pmid: 20423280].
9 Sapienza AD, Francisco RP, Trindade TC, et al. Factors predicting the need for insulin therapy in patients with gestational diabetes mellitus. Diabetes Res Clin Pract. 2010;88(1):81-6. [pmid: 20071050].
10 Patel S, Fraser A, Davey SG, et al. Associations of gestational diabetes, existing diabetes, and glycosuria with offspring obesity and cardiometabolic outcomes. Diabetes Care. 2012;35(1):63-71. [pmid: 22124718].
11 Renar IP, Tomic M, Horvat B, Metelko Z. Screening and intervention in getational diabetes mellitus. Diabetologia. 1997;40(suppl 1):848.

## Excluded – Unobtainable (N=7)

1 Bell AW. Insulin Resistance in Pregnancy: Implications for Gestational Diabetes Source: In: Nutrition Society of Australia; p. 11-19; The Society; 1995 Series: Proceedings – Nutrition Society of Australia. Number: Vol 19 ISSN: 0314-1004 Language: English. Melbourne, Australia.
2 Mori M, Dolci M, Baccetti F. Evaluation after 1, 2, 3 years to delivery of glucose tolerance in women with gestational diabetes and of son's development anthropometric. 1997.
3 Meyer WJ, Carbone J, Gauthier DW, et al. Early gestational glucose screening and gestational diabetes. J Reprod Med. 1996;41(9):675-9. [pmid: 8887193].
4 Gorgojo Martinez JJ, Almodovar Ruiz F, Lopez Hernandez E, et al. Incidence of gestational diabetes mellitus according to different diagnostic criteria in the southeast Madrid area. Influence of diagnosis on materno-fetal parameters. Rev Clin Esp. 2002;202(3):136-41. [pmid: 11996740].
5 Fan ZT, Yang HX, Gao XL, et al. Pregnancy outcome in gestational diabetes. Int J Gynaecol Obstet. 2006;94(1):12-6. [pmid: 16733056].
6 Eslamian L, Ramezani Z. Breakfast as a screening test for gestational diabetes. Int J Gynaecol Obstet. 2007;96(1):34-5. [pmid: 17188692].
7 Cheng YW, Block-Kurbisch I, Lydell J, Caughey AB. 2008. (missing reference data).
8 Sultan M, Khlaif H. Impact of gestational impaired glucose tolerance test (GIGTT) on pregnancy outcome. Jamahiriya Med J. 2010;10(4):268-71.