# Evidence Tables

Table D1 Characteristics of studies examining properties of current screening and diagnostic tests for GDM, Key Question 1

Table D2 Characteristics of studies comparing outcomes for women who were and were not screened for GDM, Key Question 2

Table D3 Characteristics of studies examining outcomes of mothers and offspring in the absence of treatment, Key Question 3

Table D4 Characteristics of studies examining treatment outcomes of mothers and offspring, Key Questions 4 and 5