# Methodological Quality of Included Studies

Table C1 Methodological quality of diagnostic studies using QUADAS-2 for Key Question 1

Author, Year Study design | 1. Patient Selection^*^ | | | | 2. Index Test^*^ | | | | 3. Reference Standard^*^ | | | | 4. Flow and Timing^*^
Author, Year Study design | a. sample | b. exclusion | c. low risk of bias | d. applicable | a. reference results not known | b. threshold | c. low risk of bias | d. applicable | a. likely to classify | b. index results not known | c. low risk of bias | d. applicable | a. interval | b. same standard | c. all included in analysis | d. low risk of bias
Agarwal, 2000 PCS | No | Yes | No | No | U | U | U | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Agarwal, 2001 PCS (34426) | No | Yes | No | No | U | Yes | U | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Agarwal, 2005a PCS | Yes | U | U | No | U | Yes | U | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Agarwal, 2005b PCS | Yes | Yes | Yes | No | U | Yes | U | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Agarwal, 2006 PCS | Yes | Yes | Yes | No | U | U | U | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Agarwal, 2008 PCS | Yes | No | U | No | U | Yes | U | Yes | Yes | U | U | Yes | Yes | Yes | Yes | Yes
Agarwal, 2011 PCS | Yes | Yes | Yes | No | U | U | U | U | Yes | U | U | Yes | Yes | Yes | Yes | Yes
Ardawi, 2000 PCS | Yes | U | U | No | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | U | U
Ayach, 2006 PCS | Yes | No | No | No | Yes | Yes | Yes | Yes | Yes | U | U | Yes | Yes | Yes | U | U
Balaji(1), 2011 PCS | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Balaji(2), 2011 PCS | Yes | Yes | Yes | No | U | Yes | U | Yes | U | Yes | U | Yes | Yes | Yes | U | U
Berkus, 1995 PCS | No | Yes | No | Yes | U | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Bobrowsk, 1996 PCS | No | Yes | No | Yes | U | Yes | U | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Brustman, 1995 PCS | No | Yes | No | Yes | U | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Buhling, 2004 PCS | Yes | Yes | Yes | U | Yes | U | U | U | U | No | U | U | Yes | Yes | No | No
Cetin, 1996 PCS | U | Yes | U | No | Yes | Yes | Yes | Yes | Yes | U | U | Yes | Yes | Yes | Yes | Yes
Chastang, 2003 PCS | No | No | No | U | No | Yes | No | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes
Chevalier, 2011 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | U | U | Yes | Yes | No | Yes | No
De los Monteros, 1999 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | U | U | Yes | Yes | Yes | No | No
Deerochanawong, 1996 PCS | U | Yes | U | No | Yes | Yes | Yes | Yes | U | U | U | Yes | Yes | No | Yes | No
Eslamian, 2008 PCS | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No | U | Yes | Yes | Yes | Yes
Gandevani, 2011 PCS | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | No | No | U | Yes | No | Yes | Yes
Hill, 2005 PCS | Yes | No | No | No | U | Yes | U | Yes | Yes | U | U | Yes | Yes | Yes | No | No
Jakobi, 2003 PCS | U | No | No | No | U | No | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Jensen, 2004 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | U | Yes | U | U
Kashi, 2007 PCS | No | No | No | No | Yes | Yes | Yes | U | Yes | No | No | Yes | U | Yes | No | No
Kauffman, 2006 PCS | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Lamar, 1999 PCS | Yes | U | U | Yes | Yes | Yes | Yes | Yes | Yes | U | U | Yes | Yes | Yes | No | No
Maegawa, 2003 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | U | U | U | Yes | No | Yes | No
Mello, 2006 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No | Yes | No
Moses, 2011 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | U | Yes | U | U | Yes | Yes | Yes | Yes
Ostlund, 2003 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | No | No | Yes | U | Yes | U | No
Perea-Carrasco, 2002 PCS | Yes | Yes | Yes | U | U | Yes | U | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Perucchini, 1999 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | U | Yes | U | U | Yes | Yes | Yes | U | Yes
Poyhonen-Alho, 2004 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | U | No | Yes | U | Yes | No | U | U
Rajput, 2012 PCS | Yes | Yes | Yes | No | No | No | No | Yes | Yes | U | U | Yes | Yes | Yes | Yes | Yes
Reichelt, 1998 PCS | Yes | U | U | No | U | No | U | U | Yes | U | U | Yes | U | Yes | U | U
Rey, 2004 PCS | Yes | U | U | Yes | Yes | Yes | Yes | Yes | Yes | U | U | Yes | U | Yes | Yes | U
Rust, 1998 PCS | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | U | U | Yes | Yes | No | Yes | Yes
Sacks, 2003 PCS | Yes | U | U | Yes | Yes | Yes | Yes | Yes | Yes | U | U | Yes | Yes | Yes | Yes | Yes
Siribaddana, 2003 PCS | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Soheilykhah, 2011 PCS | Yes | Yes | Yes | No | No | Yes | No | Yes | U | No | No | Yes | U | Yes | U | U
Soonthornpun, 2003 PCS | No | U | No | No | U | Yes | U | Yes | Yes | U | U | Yes | Yes | Yes | Yes | Yes
Tan, 2007 PCS | Yes | Yes | Yes | No | U | Yes | U | Yes | Yes | U | U | Yes | Yes | No | Yes | No
Trihospital 1998 PCS (Naylor) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Uncu, 1995 PCS | U | U | U | No | Yes | Yes | U | Yes | Yes | U | U | Yes | Yes | Yes | Yes | Yes
van Leeuwen 2007 PCS | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | U | Yes | U
Weerakiet, 2006 PCS | Yes | Yes | Yes | No | U | No | No | U | Yes | U | U | Yes | Yes | Yes | Yes | Yes
Wijeyaratne, 2006 PCS | Yes | U | U | No | Yes | U | U | U | Yes | Yes | Yes | Yes | Yes | U | Yes | U
Yachi, 2011 PCS | U | Yes | U | U | Yes | Yes | Yes | U | Yes | U | U | U | No | No | Yes | Yes
Yogev, 2004 PCS | U | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | No | U | Yes | Yes | U | Yes | U

* QUADAS domain descriptions: 1.a. Random or consecutive sample; 1.b.Did the study avoid inappropriate exclusions?; 1.c.Was the study a low risk of bias?; 1.d.Is the study applicable?; 2.a.Reference standard results not known; 2.b. Pre specified threshold; 2.c.Was the study a low risk of bias?; 2.d.Is the study applicable?; 3.a.Likely to classify target patients; 3.b.Index test results not known; 3.c.Was the study a low risk of bias?; 3.d.Is the study applicable?; 4.a.Interval between tests; 4.b.Same standard for all patients; 4.c.All patients included in analysis; 4.d.Was the study a low risk of bias?

U = unclear

Table C2 Methodological quality of randomized controlled trials (RCTs) using the Cochrane Collaboration's tool for assessing risk of bias for Key Questions 2 to 5

Author Year | Sequence generation | Allocation concealment | Blinding | | Incomplete outcome data^*^ | Selective outcome reporting | Other | Overall Risk of Bias^*^ (quality rating)^†^
Author Year | Sequence generation | Allocation concealment | Participants^*^ | Outcome assessment^*^ | Incomplete outcome data^*^ | Selective outcome reporting | Other | Overall Risk of Bias^*^ (quality rating)^†^
Bevier, 1999 | Unclear | Unclear | Unclear | Low | Unclear | Low | Low | Unclear (fair)
Bonomo, 2005 | Low | Unclear | Unclear | Low | Low | Low | Low | Unclear (fair)
Crowther, 2005 | Low | Low | Low | Low | Low | Low | Low | Low (good)
Garner, 1997 | Unclear | Unclear | Unclear | High | High | Low | Low | High (poor)
Landon, 2009 | Unclear | Unclear | Low | Low | Low | Low | Low | Unclear (fair)

* Domains for which assessments are made by outcome were assessed for objective outcomes

† Quality rating based on EPC Methods Guide (good, fair, poor)

Table C3 Methodological quality of prospective cohort studies (PCS) and retrospective cohort studies (RCS) using Newcastle-Ottawa Quality Assessment Scale, by Key Question and design

Author, Year | Representativeness of exposed cohort | Selection of non-exposed cohort | Ascertainment of exposure | Outcome of interest not present at start of study | Comparability of cohorts (Study controls) | | Assessment of outcome | Follow up long enough for outcomes to occur | Adequacy of cohort follow up | Total stars (quality rating) †
Author, Year | Representativeness of exposed cohort | Selection of non-exposed cohort | Ascertainment of exposure | Outcome of interest not present at start of study | known factors^*^ | additional factor | Assessment of outcome | Follow up long enough for outcomes to occur | Adequacy of cohort follow up | Total stars (quality rating) †
KQ2 – PCS
Solomon, 1996 | Selected group of users | Same community as exposed cohort | Structured interview | Yes | No | No | Record linkage | Yes | Subjects lost unlikely to introduce bias | 6 (fair)
KQ2 – RCS
Chanprapaph, 2004 | Truly representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
KQ3 – PCS
Ardawi, 2000 | Truly representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Subjects lost unlikely to introduce bias | 7 (good)
Lao, 2001 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | No description | Yes | Subjects lost unlikely to introduce bias | 6 (fair)
Lapolla, 2007 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | No description | Yes | Complete follow up | 8 (good)
Metzger/HAPO, 2008 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Independent blind assessment | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Retnakaran, 2008 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | No description | Yes | Subjects lost unlikely to introduce bias | 8 (good)
Sacks, 1995 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | No description | Yes | Subjects lost unlikely to introduce bias | 8 (good)
Sermer, 1995 RCT | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Shirazian, 2008 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | No description | Yes | Subjects lost unlikely to introduce bias | 8 (good)
KQ3 – RCS
Aberg, 2001 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Adams, 1998 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Berggren, 2011 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Berkus, 1995 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Biri, 2009 | Truly representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Black, 2010 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Bo, 2004 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Cheng, 2009 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Chico, 2005 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Chou, 2010 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Cok, 2011 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Corrado, 2009 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Hillier, 2007 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Independent blind assessment | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Jensen, 2002 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Kim, 2002 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Subjects lost unlikely to introduce bias | 8 (good)
Kwik, 2007 | Truly representative | Same community as exposed cohort cohort | Secure record | Yes | No | No | Record linkage | Yes | Subjects lost unlikely to introduce bias | 7 (good)
Langer, 2005 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Lao, 2003 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | No | Record linkage | Yes | Subjects lost unlikely to introduce bias | 8 (good)
Lapolla, 2011 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Morikawa, 2010 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Nord, 1995 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Subjects lost unlikely to introduce bias | 7 (good)
Pennison, 2001 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Ricart, 2005 | Truly representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Rust, 1996 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Schwartz, 1999 | Truly representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Follow up rate <75% and no description of those lost | 6 (fair)
Stamilio, 2004 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Tan, 2008 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Vambergue, 2000 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
Yang, 2002 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)
KQ4/5 – PCS
Malcolm, 2006 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Follow up rate <75% and no description of those lost | 6 (fair)
KQ4/5 – RCS
Adams, 1998 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Subjects lost unlikely to introduce bias | 9 (good)
Bonomo, 1997 | Selected group of users | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 8 (good)
Fassett, 2007 | Somewhat representative | Same community as exposed cohort | Secure record | Yes | No | No | Record linkage | Yes | Complete follow up | 7 (good)
Langer, 2005 | Truly representative | Same community as exposed cohort | Secure record | Yes | Yes | Yes | Record linkage | Yes | Complete follow up | 9 (good)

* Controls for known factors: age, race, BMI, history of GDM, family history of DM

† Quality rating based on EPC Methods Guide (good, fair, poor): total scores of 7-9 were considered good, 4-6 fair, and 0-3 poor.

BMI = body mass index; GDM = gestational diabetes mellitus; DM = diabetes mellitus; PCS = prospective cohort study; RCS = retrospective cohort study