# Review Forms

B1 Screening Criteria for Key Questions 1-5

B2 Eligibility Criteria for Key Questions 1-5

B3 Methodological Quality Assessment by Study Design

a Diagnostic studies – QUADAS-2 Tool

b Randomized controlled trials – Cochrane Collaboration’s tool for assessing risk of bias

c Cohort studies – Newcastle-Ottawa Quality Assessment Scale

B4 Data Extraction Forms

a Screening and diagnosing gestational diabetes – key question 1

b Screening and diagnosing gestational diabetes – key question 2

c Screening and diagnosing gestational diabetes – key question 3

d Screening and diagnosing gestational diabetes – key question 4 and 5