# Literature Search Strings

Table A1 Medline

Database: Medline via Ovid <1948 to September Week 4 2011>
Search Date: 9 October 2011
Results: 8,234
1. | Diabetes, Gestational/
2. | Fetal Macrosomia/
3. | Pregnancy Complications/
4. | GDM.tw.
5. | (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
6. | (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
7. | (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia)).tw.
8. | (hyperglyc?emia adj2 pregnan$).tw.
9. | macrosomia.tw.
10. | or/1-9
11. | mass screening/
12. | prenatal diagnosis/
13. | screen$.tw.
14. | ((prenatal or early) adj2 diagnosis).tw.
15. | Glucose Tolerance Test/
16. | Glucose Intolerance/
17. | Blood Glucose/
18. | Risk Factors/
19. | (glucose adj (tolerance or intolerance or challenge)).tw.
20. | OGTT.tw.
21. | GCT.tw.
22. | (fasting adj2 glucose).tw.
23. | or/11-22
24. | “Sensitivity and Specificity”/
25. | “Predictive Value of Tests”/
26. | ROC Curve/
27. | specific$.tw.
28. | sensitiv$.tw.
29. | predictive value.tw.
30. | accurac$.tw.
31. | diagnostic errors/
32. | diagnostic error?.tw.
33. | false negative reactions/
34. | false positive reactions/
35. | (false adj (negative or positive)).tw.
36. | “reproducibility of results”/
37. | reference values/
38. | reference standards/
39. | or/24-38
40. | and/10,23,39
41. | intervention?.mp.
42. | (treating or treatment? or therapy or therapies).mp.
43. | manage$.mp.
44. | monitor$.mp.
45. | exp sulfonylurea compounds/
46. | Gliclazide/
47. | Glyburide/
48. | Tolbutamide/
49. | sulfonylurea?.tw.
50. | gliclazid$.tw.
51. | glimepirid$.tw.
52. | glipizid$.tw.
53. | glyburid$.tw.
54. | tolbutamid$.tw.
55. | (antidiabet$ or anti-diabet$).tw.
56. | insulin?.mp.
57. | glibenclamid$.mp.
58. | acarbos$.mp.
59. | exp Diet Therapy/
60. | (diet adj2 (therap$ or restrict$ or advice)).tw.
61. | medical nutrition$ therapy.tw.
62. | MNT.tw.
63. | exp Life Style/
64. | (lifestyle$ or life-style$).mp.
65. | Blood Glucose Self-Monitoring/
66. | (blood glucose adj (self monitor$ or self-monitor$)).tw.
67. | ((self monitor$ or self-monitor$) adj blood glucose).tw.
68. | SMBG.tw.
69. | Counseling/
70. | counsel$.tw.
71. | Labor, Induced/
72. | (induc$ adj2 labo?r).tw.
73. | exp Cesarean Section/
74. | c?esarean.tw.
75. | exp Pregnancy Outcome/
76. | pregnanc$ outcome?.tw.
77. | or/41-76
78. | and/10,77
79. | or/40,78
80. | clinical trial.pt.
81. | randomized controlled trial.pt.
82. | randomi?ed.ti,ab.
83. | placebo.ti,ab.
84. | dt.fs.
85. | randomly.ti,ab.
86. | trial.ti,ab.
87. | groups.ti,ab.
88. | or/80-87
89. | animals/
90. | humans/
91. | 89 not (89 and 90)
92. | 88 not 91
93. | cohort studies/
94. | follow-up studies/
95. | longitudinal studies/
96. | prospective studies/
97. | retrospective studies/
98. | ((cohort? or follow-up or followup or longitud$ or prospectiv$ or retrospectiv$) adj (study or studies or trial?)).tw.
99. | or/93-98
100. | 99 not 91
101. | exp Guideline/
102. | Health Planning Guidelines/
103. | (clinical adj2 guideline?).tw.
104. | CPG?.tw.
105. | ((practice or consensus or position) adj2 (guideline? or recommendation? or statement?)).tw.
106. | standard?.tw.
107. | protocol?.tw.
108. | or/101-107
109. | meta analysis.mp,pt.
110. | review.pt.
111. | search:.tw.
112. | or/109-111 [Reviews balanced - HIRU]
113. | and/79,92 [Clinical trials & RCTs]
114. | and/79,100 [Observational studies]
115. | and/79,108 [Guidelines]
116. | and/79,112 [SRs MAs]
117. | or/113-116
118. | limit 117 to (english language and yr=“2000 -Current”)
119. | limit 117 to (english language and yr=“2000 -2005”)
120. | limit 117 to (english language and yr=“2006 -Current”)
121. | remove duplicates from 119
122. | remove duplicates from 120
123. | or/121-122
124. | 113 or 114 or 115
125. | 113 or 114 or 115
126. | limit 125 to (english language and yr=“2000 -Current”)
127. | limit 125 to (english language and yr=“2000 -2005”)
128. | remove duplicates from 127
129. | limit 125 to (english language and yr=“2006 -Current”)
130. | remove duplicates from 129
131. | 128 or 130
132. | 113 or 114
133. | limit 132 to (english language and yr=“2000 -Current”)
134. | limit 132 to (english language and yr=“2000 -2005”)
135. | remove duplicates from 134
136. | limit 132 to (english language and yr=“2006 -Current”)
137. | remove duplicates from 136
138. | 135 or 137

Table A2 Embase

Database: Embase via Ovid <1996 to 2011 Week 40>
Search Date: 10 October 2011
Results: 5,188
1. | pregnancy diabetes mellitus/
2. | maternal diabetes mellitus/
3. | pregnancy complication/
4. | macrosomia/
5. | GDM.tw.
6. | (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
7. | (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
8. | (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia)).mp.
9. | (hyperglyc?emia adj2 pregnan$).tw.
10. | macrosomia.tw.
11. | or/1-10
12. | prenatal screening/
13. | early diagnosis/
14. | screen$.tw.
15. | ((prenatal or early) adj2 diagnosis).tw.
16. | exp glucose tolerance test/
17. | glucose intolerance/
18. | glucose blood level/
19. | risk factor/
20. | (glucose adj (tolerance or intolerance or challenge)).tw.
21. | OGTT.tw.
22. | GCT.tw.
23. | (fasting adj2 glucose).tw.
24. | or/12-23
25. | “sensitivity and specificity”/
26. | predictive value/
27. | receiver operating characteristic/
28. | specific$.tw.
29. | sensitiv$.tw.
30. | predictive value.tw.
31. | accurac$.tw.
32. | diagnostic error/
33. | diagnostic accuracy/
34. | diagnostic error?.tw.
35. | false negative result/
36. | false positive result/
37. | (false adj (negative or positive)).tw.
38. | reproducibility/
39. | reference value/
40. | standard/
41. | or/25-40
42. | and/11,24,41
43. | intervention?.mp.
44. | (treating or treatment? or therapy or therapies).mp.
45. | manage$.mp.
46. | monitor$.mp.
47. | sulfonylurea derivative/
48. | gliclazide/
49. | glibenclamide/
50. | glimepiride/
51. | glipizide/
52. | tolbutamide/
53. | sulfonylurea?.tw.
54. | gliclazid$.tw.
55. | glimepirid$.tw.
56. | glipizid$.tw.
57. | glyburid$.tw.
58. | tolbutamid$.tw.
59. | (antidiabet$ or anti-diabet$).tw.
60. | insulin?.mp.
61. | glibenclamid$.mp.
62. | acarbos$.mp.
63. | exp diet therapy/
64. | (diet adj2 (therap$ or restrict$ or advice)).tw.
65. | medical nutrition$ therapy.tw.
66. | MNT.tw.
67. | exp lifestyle/
68. | (lifestyle$ or life-style$).mp.
69. | blood glucose monitoring/
70. | (blood glucose adj (self monitor$ or self-monitor$)).tw.
71. | ((self monitior$ or self-monitor$) adj blood glucose).tw.
72. | SMBG.tw.
73. | counseling/
74. | nutritional counseling/
75. | counsel$.tw.
76. | labor induction/
77. | (induc$ adj2 labo?r).tw.
78. | cesarean section/
79. | c?esarean.tw.
80. | pregnancy outcome/
81. | pregnanc$ outcome?.tw.
82. | or/43-81
83. | and/11,82
84. | or/42,83
85. | clinical trial/
86. | randomized controlled trial/
87. | randomization/
88. | single blind procedure/
89. | double blind procedure/
90. | crossover procedure/
91. | placebo/
92. | randomi?ed controlled trial?.tw.
93. | RCT.tw.
94. | random allocation.tw.
95. | randomly allocated.tw.
96. | allocated randomly.tw.
97. | (allocated adj2 random).tw.
98. | single blind$.tw.
99. | double blind$.tw.
100. | ((treble or triple) adj blind$).tw.
101. | placebo$.tw.
102. | prospective study/
103. | or/85-102
104. | case study/
105. | case report.tw.
106. | abstract report/ or letter/
107. | or/104-106
108. | 103 not 107 [SIGN Embase RCT filter]
109. | animal/
110. | human/
111. | 109 not (109 and 110)
112. | 108 not 111
113. | cohort analysis/
114. | follow up/
115. | longitudinal study/
116. | prospective study/
117. | retrospective study/
118. | ((cohort? or follow-up or followup or longitud$ or prospectiv$ or retrospectiv$) adj (study or studies or trial?)).tw.
119. | or/113-118
120. | 119 not 111
121. | exp practice guideline/
122. | (clinical adj2 guideline?).tw.
123. | CPG?.tw.
124. | ((practice or consensus or position) adj2 (guideline? or recommendation? or statement?)).tw.
125. | standard?.tw.
126. | protocol?.tw.
127. | or/121-126 [Guidelines]
128. | and/84,112 [RCTs]
129. | and/84,120 [Observational studies]
130. | and/84,127 [Guidelines]
131. | or/128-130
132. | limit 131 to (english language and yr=“2000 -2005”)
133. | remove duplicates from 132
134. | limit 131 to (english language and yr=“2006 -Current”)
135. | remove duplicates from 134 133 or 135

Table A3 EMB Reviews

Databases:
Cochrane Central Register of Controlled Trials (CCTR) via Ovid <3^rd^ Quarter 2011>
Cochrane Database of Systematic Reviews (CDSR) via Ovid <2005 to September 2011>
Database of Abstracts of Reviews of Effects (DARE) via Ovid <3^rd^ Quarter 2011>
Search Date: 9 October 2011
Results: CCTR: 23; CDSR: 79; DARE: 23
1. | GDM.tw.
2. | (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
3. | (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
4. | (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia)).tw.
5. | (hyperglyc?emia adj2 pregnan$).tw.
6. | macrosomia.tw.
7. | or/1-6
8. | screen$.tw.
9. | ((prenatal or early) adj2 diagnosis).tw.
10. | blood glucose.tw.
11. | risk factor?.tw.
12. | (glucose adj (tolerance or intolerance or challenge)).tw.
13. | OGTT.tw.
14. | GCT.tw.
15. | (fasting adj2 glucose).tw.
16. | or/8-15
17. | specific$.tw.
18. | sensitiv$.tw.
19. | predictive value.tw.
20. | (ROC or “receiver operating characteristic?”).tw.
21. | accurac$.tw.
22. | diagnostic error?.tw.
23. | (false adj (negative or positive)).tw.
24. | “reproducibility of results”.tw.
25. | (reference adj2 (standard? or value?)).tw.
26. | or/17-25
27. | and/7,16,26
28. | intervention?.mp.
29. | (treating or treatment? or therapy or therapies).mp.
30. | manage$.mp.
31. | monitor$.mp.
32. | sulfonylurea?.tw.
33. | gliclazid$.tw.
34. | glimepirid$.tw.
35. | glipizid$.tw.
36. | glyburid$.tw.
37. | tolbutamid$.tw.
38. | (antidiabet$ or anti-diabet$).tw.
39. | insulin?.mp.
40. | glibenclamid$.mp.
41. | acarbos$.mp.
42. | (diet adj2 (therap$ or restrict$ or advice)).tw.
43. | medical nutrition$ therapy.tw.
44. | MNT.tw.
45. | (lifestyle$ or life-style$).mp.
46. | (blood glucose adj (self monitor$ or self-monitor$)).tw.
47. | ((self monitior$ or self-monitor$) adj blood glucose).tw.
48. | SMBG.tw.
49. | counsel$.tw.
50. | (induc$ adj2 labo?r).tw.
51. | c?esarean.tw.
52. | pregnanc$ outcome?.tw.
53. | or/28-52
54. | and/7,53
55. | or/27,54
56. | clinical trial.pt.
57. | randomized controlled trial.pt.
58. | randomi?ed.ti,ab.
59. | placebo.ti,ab.
60. | dt.fs.
61. | randomly.ti,ab.
62. | trial.ti,ab.
63. | groups.ti,ab.
64. | or/56-63
65. | (animal? not (animal? and human?)).mp.
66. | 64 not 65
67. | ((cohort? or follow-up or followup or longitud$ or prospectiv$ or retrospectiv$) adj (study or studies or trial?)).tw.
68. | 67 not 66
69. | (clinical adj2 guideline?).tw.
70. | CPG?.tw.
71. | ((practice or consensus or position) adj2 (guideline? or recommendation? or statement?)).tw.
72. | standard?.tw.
73. | protocol?.tw.
74. | or/69-73
75. | and/55,66 [Clinical trials & RCTs]
76. | and/55,68 [Observational studies]
77. | and/55,74 [Guidelines]
78. | or/75-77
79. | limit 78 to (english language and yr=“2000-Current”)
80. | remove duplicates from 79

Table A4 Global Health

Database: Global Health via Ovid <1973 to September 2011>
Search Date: 9 October 2011
Results: 361
1. | GDM.tw.
2. | (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
3. | (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
4. | (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia)).tw.
5. | (hyperglyc?emia adj2 pregnan$).tw.
6. | macrosomia.tw.
7. | or/1-6
8. | screen$.tw.
9. | ((prenatal or early) adj2 diagnosis).tw.
10. | blood glucose.tw.
11. | risk factor?.tw.
12. | (glucose adj (tolerance or intolerance or challenge)).tw.
13. | OGTT.tw.
14. | GCT.tw.
15. | (fasting adj2 glucose).tw.
16. | or/8-15
17. | specific$.tw.
18. | sensitiv$.tw.
19. | predictive value.tw.
20. | (ROC or “receiver operating characteristic?”).tw.
21. | accurac$.tw.
22. | diagnostic error?.tw.
23. | (false adj (negative or positive)).tw.
24. | “reproducibility of results”.tw.
25. | (reference adj2 (standard? or value?)).tw.
26. | or/17-25
27. | and/7,16,26
28. | intervention?.mp.
29. | (treating or treatment? or therapy or therapies).mp.
30. | manage$.mp.
31. | monitor$.mp.
32. | sulfonylurea?.tw.
33. | gliclazid$.tw.
34. | glimepirid$.tw.
35. | glipizid$.tw.
36. | glyburid$.tw.
37. | tolbutamid$.tw.
38. | (antidiabet$ or anti-diabet$).tw.
39. | insulin?.mp.
40. | glibenclamid$.mp.
41. | acarbos$.mp.
42. | (diet adj2 (therap$ or restrict$ or advice)).tw.
43. | medical nutrition$ therapy.tw.
44. | MNT.tw.
45. | (lifestyle$ or life-style$).mp.
46. | (blood glucose adj (self monitor$ or self-monitor$)).tw.
47. | ((self monitior$ or self-monitor$) adj blood glucose).tw.
48. | SMBG.tw.
49. | counsel$.tw.
50. | (induc$ adj2 labo?r).tw.
51. | c?esarean.tw.
52. | pregnanc$ outcome?.tw.
53. | or/28-52
54. | and/7,53
55. | or/27,54
56. | clinical trial.pt.
57. | randomized controlled trial.pt.
58. | randomi?ed.ti,ab.
59. | placebo.ti,ab.
60. | dt.fs.
61. | randomly.ti,ab.
62. | trial.ti,ab.
63. | groups.ti,ab.
64. | or/56-63
65. | (animal? not (animal? and human?)).mp.
66. | 64 not 65
67. | ((cohort? or follow-up or followup or longitud$ or prospectiv$ or retrospectiv$) adj (study or studies or trial?)).tw.
68. | 67 not 66
69. | (clinical adj2 guideline?).tw.
70. | CPG?.tw.
71. | ((practice or consensus or position) adj2 (guideline? or recommendation? or statement?)).tw.
72. | standard?.tw.
73. | protocol?.tw.
74. | or/69-73
75. | and/55,66 [Clinical trials & RCTs]
76. | and/55,68 [Observational studies]
77. | and/55,74 [Guidelines]
78. | or/75-77
79. | limit 78 to (english language and yr=“2000-Current”)
80. | remove duplicates from 79

Table A5 PASCAL

Database: PASCAL via Ovid <1984 to 2011 Week 39>
Search Date: 9 October 2011
Results: 498
1. | GDM.tw.
2. | (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
3. | (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
4. | (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia)).tw.
5. | (hyperglyc?emia adj2 pregnan$).tw.
6. | macrosomia.tw.
7. | or/1-6
8. | screen$.tw.
9. | ((prenatal or early) adj2 diagnosis).tw.
10. | blood glucose.tw.
11. | risk factor?.tw.
12. | (glucose adj (tolerance or intolerance or challenge)).tw.
13. | OGTT.tw.
14. | GCT.tw.
15. | (fasting adj2 glucose).tw.
16. | or/8-15
17. | specific$.tw.
18. | sensitiv$.tw.
19. | predictive value.tw.
20. | (ROC or “receiver operating characteristic?”).tw.
21. | accurac$.tw.
22. | diagnostic error?.tw.
23. | (false adj (negative or positive)).tw.
24. | “reproducibility of results”.tw.
25. | (reference adj2 (standard? or value?)).tw.
26. | or/17-25
27. | and/7,16,26
28. | intervention?.mp.
29. | (treating or treatment? or therapy or therapies).mp.
30. | manage$.mp.
31. | monitor$.mp.
32. | sulfonylurea?.tw.
33. | gliclazid$.tw.
34. | glimepirid$.tw.
35. | glipizid$.tw.
36. | glyburid$.tw.
37. | tolbutamid$.tw.
38. | (antidiabet$ or anti-diabet$).tw.
39. | insulin?.mp.
40. | glibenclamid$.mp.
41. | acarbos$.mp.
42. | (diet adj2 (therap$ or restrict$ or advice)).tw.
43. | medical nutrition$ therapy.tw.
44. | MNT.tw.
45. | (lifestyle$ or life-style$).mp.
46. | (blood glucose adj (self monitor$ or self-monitor$)).tw.
47. | ((self monitior$ or self-monitor$) adj blood glucose).tw.
48. | SMBG.tw.
49. | counsel$.tw.
50. | (induc$ adj2 labo?r).tw.
51. | c?esarean.tw.
52. | pregnanc$ outcome?.tw.
53. | or/28-52
54. | and/7,53
55. | or/27,54
56. | clinical trial.pt.
57. | randomized controlled trial.pt.
58. | randomi?ed.ti,ab.
59. | placebo.ti,ab.
60. | dt.fs.
61. | randomly.ti,ab.
62. | trial.ti,ab.
63. | groups.ti,ab.
64. | or/56-63
65. | (animal? not (animal? and human?)).mp.
66. | 64 not 65
67. | ((cohort? or follow-up or followup or longitud$ or prospectiv$ or retrospectiv$) adj (study or studies or trial?)).tw.
68. | 67 not 66
69. | (clinical adj2 guideline?).tw.
70. | CPG?.tw.
71. | ((practice or consensus or position) adj2 (guideline? or recommendation? or statement?)).tw.
72. | standard?.tw.
73. | protocol?.tw.
74. | or/69-73
75. | and/55,66 [Clinical trials & RCTs]
76. | and/55,68 [Observational studies]
77. | and/55,74 [Guidelines]
78. | or/75-77
79. | limit 78 to (english language and yr=”2000-Current”)
80. | remove duplicates from 79

Table A6 Medline In-Process & Other Non-Indexed Citations

Database: Medline In-Process & Other Non-Indexed Citations <October 7, 2011>
Search Date: 7 October 2011
Results: 98
1. | GDM.tw.
2. | (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
3. | (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
4. | (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia)).tw.
5. | (hyperglyc?emia adj2 pregnan$).tw.
6. | macrosomia.tw.
7. | or/1-6
8. | screen$.tw.
9. | ((prenatal or early) adj2 diagnosis).tw.
10. | blood glucose.tw.
11. | risk factor?.tw.
12. | (glucose adj (tolerance or intolerance or challenge)).tw.
13. | OGTT.tw.
14. | GCT.tw.
15. | (fasting adj2 glucose).tw.
16. | or/8-15
17. | specific$.tw.
18. | sensitiv$.tw.
19. | predictive value.tw.
20. | (ROC or “receiver operating characteristic?”).tw.
21. | accurac$.tw.
22. | diagnostic error?.tw.
23. | (false adj (negative or positive)).tw.
24. | “reproducibility of results”.tw.
25. | (reference adj2 (standard? or value?)).tw.
26. | or/17-25
27. | and/7,16,26
28. | intervention?.mp.
29. | (treating or treatment? or therapy or therapies).mp.
30. | manage$.mp.
31. | monitor$.mp.
32. | sulfonylurea?.tw.
33. | gliclazid$.tw.
34. | glimepirid$.tw.
35. | glipizid$.tw.
36. | glyburid$.tw.
37. | tolbutamid$.tw.
38. | (antidiabet$ or anti-diabet$).tw.
39. | insulin?.mp.
40. | glibenclamid$.mp.
41. | acarbos$.mp.
42. | (diet adj2 (therap$ or restrict$ or advice)).tw.
43. | medical nutrition$ therapy.tw.
44. | MNT.tw.
45. | (lifestyle$ or life-style$).mp.
46. | (blood glucose adj (self monitor$ or self-monitor$)).tw.
47. | ((self monitior$ or self-monitor$) adj blood glucose).tw.
48. | SMBG.tw.
49. | counsel$.tw.
50. | (induc$ adj2 labo?r).tw.
51. | c?esarean.tw.
52. | pregnanc$ outcome?.tw.
53. | or/28-52
54. | and/7,53
55. | or/27,54
56. | clinical trial.pt.
57. | randomized controlled trial.pt.
58. | randomi?ed.ti,ab.
59. | placebo.ti,ab.
60. | dt.fs.
61. | randomly.ti,ab.
62. | trial.ti,ab.
63. | groups.ti,ab.
64. | or/56-63
65. | (animal? not (animal? and human?)).mp.
66. | 64 not 65
67. | ((cohort? or follow-up or followup or longitud$ or prospectiv$ or retrospectiv$) adj (study or studies or trial?)).tw.
68. | 67 not 66
69. | (clinical adj2 guideline?).tw.
70. | CPG?.tw.
71. | ((practice or consensus or position) adj2 (guideline? or recommendation? or statement?)).tw.
72. | standard?.tw.
73. | protocol?.tw.
74. | or/69-73
75. | and/55,66 [Clinical trials & RCTs]
76. | and/55,68 [Observational studies]
77. | and/55,74 [Guidelines]
78. | or/75-77
79. | limit 78 to (english language and yr=“2000-Current”)
80. | remove duplicates from 79

Table A7 CINAHL Plus with Full Text

Database: CINAHL Plus with Full Text via EBSCO <1937–current>
Search Date: 10 October 2011
Results: 275
S39= S35 or S37 or S38 S38= S25 and S33 Limiters - English Language; Published Date from: 20000101-20121231; Exclude MEDLINE records S37= S25 and S32 Limiters - English Language; Published Date from: 20000101-20121231; Exclude MEDLINE records S36= S25 and S32 S35= S25 and S31 Limiters - English Language; Published Date from: 20000101-20121231; Exclude MEDLINE records S34= S25 and S31 S33=( CPG? or “best practice?” or “professional standard?” or “standard of care” ) OR ( practice W2 guideline* or practice W2 recommendation* or practice W2 statement or position W2 guideline* or position W2 recommendation* or position W2 statement or consensus W2 guideline* or consensus W2 recommendation* or consensus W2 statement ) S32=( (MH “Prospective Studies+”) OR (MH “Retrospective Design”) ) OR TI ( cohort* or follow-up or followup or longitud* or prospectiv* or retrospective* ) OR AB ( cohort* or follow-up or followup or longitud* or prospectiv* or retrospective* ) S31= S26 or S27 or S28 or S29 or S30 S30=(MH “Placebos”) OR TX placebo* OR (MH “Quantitative Studies”) S29= TX randomi* control* trial* OR (MH “Random Assignment”) OR TX random* allocat* OR TX allocat* random* S28= TX clinic* n1 trial* OR ( TX ( (singl* n1 blind*) or (singl* n1 mask*) ) or TX ( (doubl* n1 blind*) or (doubl* n1 mask*) ) or TX ( (tripl* n1 blind*) or (tripl* n1 mask*) ) or TX ( (trebl* n1 blind*) or (trebl* n1 mask*) ) ) S27= PT Clinical trial S26=(MH “Clinical Trials+”) S25= S14 or S24 S24= S5 and S23 S23= S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 S22=( (MH “Labor, Induced”) OR (MH “Cesarean Section+”) OR (MH “Pregnancy Outcomes”) ) OR ( induc* n2 labo#r or cesarean or caesarean or pregnan* n1 outcome* ) S21=( (MH “Counseling”) OR (MH “Nutritional Counseling”) ) OR counsel* S20=(MH “Blood Glucose Self-Monitoring”) OR ( “blood glucose” w1 “self monitor*” or “blood glucose” w1 “self-monitor*” ) OR SMBG S19=(MH “Life Style Changes”) OR ( lifestyle* or life-style* ) S18=(MH “Diet Therapy”) OR ( diet w2 therap* or diet w2 restrict* or diet w2 advice ) OR ( “medical nutrition therapy” or MNT ) S17=( sulfonyurea? or gliclazid* or glimepirid* or glipizid* or glyburid* or tolbutamid* ) OR ( antidiabet* or anti-diabet* ) OR ( insulin* or glibenclamid* or acarbos* ) S16=(MH “Sulfonylurea Compounds+”) S15= intervention* or treating or treatment* or therapy or therapies or manage* or monitor* S14= S5 and S10 and S13 S13= S11 or S12 S12=( specific* or sensitiv* or predictive w1 value* or accurac* or diagnostic w1 error* ) OR ( false w1 negative or false w1 positive ) S11=(MH “Diagnostic Errors”) OR (MH “Reproducibility of Results”) OR (MH “False Negative Results”) OR (MH “False Positive Results”) OR (MH “Predictive Value of Tests”) OR (MH “Sensitivity and Specificity”) OR (MH “ROC Curve”) OR (MH “Reference Values”) S10= S6 or S7 or S8 or S9 S9=( glucose n1 tolerance or glucose n1 intolerance or glucose n1 challenge ) OR ( OGTT or GCT ) OR fasting w2 glucose S8=(MH “Glucose Tolerance Test”) OR (MH “Blood Glucose Monitoring”) OR (MH “Glucose Intolerance”) OR (MH “Blood Glucose”) OR (MH “Risk Assessment”) S7= screen* OR ( prenatal n2 diagnosis or early n2 diagnosis ) S6=(MH “Neonatal Assessment”) OR (MH “Health Screening+”) OR (MH “Prenatal Diagnosis+”) S5= S1 or S2 or S3 or S4 S4= hyperglyc#emia n2 pregnan* OR macrosomia S3=( gestation* n2 diabet* or gestation* n2 DM or gestation* n2 glucose intoleran* or gestation* n2 insulin resistan* ) OR ( pregnan* n2 diabet* or pregnan* n2 DM or pregnan* n2 glucose intoleran* or pregnan* n2 insulin resistan* ) OR ( maternal n2 diabet* or maternal n2 DM or maternal n2 glucose intoleran* or maternal n2 insulin resistan* ) S2=( (MM “Diabetes Mellitus, Gestational”) OR (MH “Pregnancy Complications”) OR (MH “Fetal Macrosomia”) ) OR GDM S1=(MM “Diabetes Mellitus, Gestational”) OR (MH “Pregnancy Complications”) OR (MH “Fetal Macrosomia”)

Table A8 BIOSIS Preview®

Database: Biosis Previews ® via Web of Knowledge^SM^ <1926–present>
Search Date: 9 October 2011
Results: 34
# 17 | (#16 OR #15 OR #14) AND Language=(English)
# 16 | (#9) AND Language=(English) AND Document Types=(Meeting OR Meeting Paper) AND Literature Type=(Meeting Abstract OR Meeting Address OR Meeting Paper OR Meeting Poster OR Meeting Report OR Meeting Slide OR Meeting Summary)
# 15 | (#13 AND #9) AND Language=(English
# 14 | (#12 AND #9) AND Language=(English
# 13 | (TS=( CPG* OR “best practice*” OR “professional standard*” OR “standard of care” OR (practice NEAR/2 guideline*) OR (practice NEAR/2 recommendation*) OR (practice NEAR/2 statement) OR (position NEAR/2 guideline*) OR (position NEAR/2 recommendation*) OR (position NEAR/2 statement) OR (consensus NEAR/2 guideline*) OR (consensus NEAR/2 recommendation*) OR (consensus NEAR/2 statement))) AND Language=(English)
# 12 | (#10 NOT #11) AND Language=(English)
# 11 | (TS=(animal* OR rat OR rats OR mouse OR mice OR rodent* OR rabbit OR rabbits OR horse OR horses OR equine OR veterinar* OR bovine OR cow OR cows OR pig OR pigs OR porcine)) AND Language=(English)
# 10 | ((TS=(randomized controlled trial* OR controlled clinical trial* OR research design OR placebo* OR random*) OR TS=(cohort* OR longitude* OR prospectiv* OR retrospectiv* OR long term OR long-term OR longterm OR followup OR “follow up” OR follow-up) AND TS=(study OR studies OR trial))) AND Language=(English)
# 9 | (#8 OR #4) AND Language=(English)
# 8 | (#7 AND #1) AND Language=(English)
# 7 | (#6 OR #5) AND Language=(English)
# 6 | TS= ((diet NEAR/2 therap*) OR (diet NEAR/2 restrict*) OR (diet NEAR/2 advice) OR “medical nutrition* therapy” OR MNT OR lifestyle* OR life-style* OR (“blood glucose” NEAR self-monitor*) OR (“blood glucose” NEAR “self monitor*”) OR SMBG OR counsel* OR (induc* NEAR labour) OR (induc* NEAR labor) OR cesarean OR caesarean OR (pregnan* NEAR outcome*))) AND Language=(English)
# 5 | TS= (intervention* OR treat* OR therap* OR sulfonylurea* OR antidiabet* OR anti-diabet* OR gliclazid* OR glimepirid* OR glipizid* OR glyburid* OR tolbutamid* OR antidiabet* OR anti-diabet* OR insulin* OR glibenclamid* OR acarbos*)) AND Language=(English)
# 4 | #3 AND #2 AND #1
# 3 | TS=(“sensitivity and specificity” OR sensitiv* OR specific* OR “predictive value” OR (diagnos* NEAR error*) OR “false negative” OR “false positive” OR accurac*)) AND Language=(English)
# 2 | TS=( “prenatal screen*” OR (glucose NEAR/3 tolerance) OR (glucose NEAR/3 intoleran*) OR (glucose NEAR/3 challenge*) OR OGTT OR GCT OR “fasting glucose” OR “risk factor* “)) AND Language=(English)
# 1 | TS= ((gestation* NEAR/2 diabet*) OR (gestation* NEAR/2 “glucose intoleran*”) OR (gestation* NEAR/2 “insulin resist*”) OR (pregnan* NEAR/2 diabet*) OR (pregnan* NEAR/2 “glucose intoleran*”) OR (pregnan* NEAR/2 “insulin resist*”) OR (maternal NEAR/2 diabet*) OR (maternal NEAR/2 “glucose intoleran*”) OR (maternal NEAR/2 “insulin resist*”) OR (hyperglycemia NEAR/2 pregnan*) OR (hyperglycaemia NEAR/2 pregnan*) OR macrosomia OR GDM)) AND Language=(English)

Table A9 Science Citation Index Expanded®

Database: Science Citation Index Expanded (SCI-EXPANDED) via Web of Knowledge^SM^ <1899–present>
Search Date: 9 October 2011
Results: 2,308
# 17 | (#16 OR #15 OR #14) AND Language=(English)
# 16 | (#9) AND Language=(English) AND Document Types=(Meeting OR Meeting Paper) AND Literature Type=(Meeting Abstract OR Meeting Address OR Meeting Paper OR Meeting Poster OR Meeting Report OR Meeting Slide OR Meeting Summary)
# 15 | (#13 AND #9) AND Language=(English
# 14 | (#12 AND #9) AND Language=(English
# 13 | (TS=( CPG* OR “best practice*” OR “professional standard*” OR “standard of care” OR (practice NEAR/2 guideline*) OR (practice NEAR/2 recommendation*) OR (practice NEAR/2 statement) OR (position NEAR/2 guideline*) OR (position NEAR/2 recommendation*) OR (position NEAR/2 statement) OR (consensus NEAR/2 guideline*) OR (consensus NEAR/2 recommendation*) OR (consensus NEAR/2 statement))) AND Language=(English)
# 12 | (#10 NOT #11) AND Language=(English)
# 11 | (TS=(animal* OR rat OR rats OR mouse OR mice OR rodent* OR rabbit OR rabbits OR horse OR horses OR equine OR veterinar* OR bovine OR cow OR cows OR pig OR pigs OR porcine)) AND Language=(English)
# 10 | ((TS=(randomized controlled trial* OR controlled clinical trial* OR research design OR placebo* OR random*) OR TS=(cohort* OR longitude* OR prospectiv* OR retrospectiv* OR long term OR long-term OR longterm OR followup OR “follow up” OR follow-up) AND TS=(study OR studies OR trial))) AND Language=(English)
# 9 | (#8 OR #4) AND Language=(English)
# 8 | (#7 AND #1) AND Language=(English)
# 7 | (#6 OR #5) AND Language=(English)
# 6 | TS= ((diet NEAR/2 therap*) OR (diet NEAR/2 restrict*) OR (diet NEAR/2 advice) OR “medical nutrition* therapy” OR MNT OR lifestyle* OR life-style* OR (“blood glucose” NEAR self-monitor*) OR (“blood glucose” NEAR “self monitor*”) OR SMBG OR counsel* OR (induc* NEAR labour) OR (induc* NEAR labor) OR cesarean OR caesarean OR (pregnan* NEAR outcome*))) AND Language=(English)
# 5 | TS= (intervention* OR treat* OR therap* OR sulfonylurea* OR antidiabet* OR anti-diabet* OR gliclazid* OR glimepirid* OR glipizid* OR glyburid* OR tolbutamid* OR antidiabet* OR anti-diabet* OR insulin* OR glibenclamid* OR acarbos*)) AND Language=(English)
# 4 | #3 AND #2 AND #1
# 3 | TS=(“sensitivity and specificity” OR sensitiv* OR specific* OR “predictive value” OR (diagnos* NEAR error*) OR “false negative” OR “false positive” OR accurac*)) AND Language=(English)
# 2 | TS=( “prenatal screen*” OR (glucose NEAR/3 tolerance) OR (glucose NEAR/3 intoleran*) OR (glucose NEAR/3 challenge*) OR OGTT OR GCT OR “fasting glucose” OR “risk factor* ”)) AND Language=(English)
# 1 | TS= ((gestation* NEAR/2 diabet*) OR (gestation* NEAR/2 “glucose intoleran*”) OR (gestation* NEAR/2 “insulin resist*”) OR (pregnan* NEAR/2 diabet*) OR (pregnan* NEAR/2 “glucose intoleran*”) OR (pregnan* NEAR/2 “insulin resist*”) OR (maternal NEAR/2 diabet*) OR (maternal NEAR/2 “glucose intoleran*”) OR (maternal NEAR/2 “insulin resist*”) OR (hyperglycemia NEAR/2 pregnan*) OR (hyperglycaemia NEAR/2 pregnan*) OR macrosomia OR GDM)) AND Language=(English)

Table A10 Conference Proceedings Citation Index–Science

Database: Conference Proceedings Citation Index- Science [CPCI-S] via Web of Science^SM^ <1990–present>
Search Date: 9 October 2011
Results: 562
# 17 | (#16 OR #15 OR #14) AND Language=(English)
# 16 | (#9) AND Language=(English) AND Document Types=(Meeting OR Meeting Paper) AND Literature Type=(Meeting Abstract OR Meeting Address OR Meeting Paper OR Meeting Poster OR Meeting Report OR Meeting Slide OR Meeting Summary)
# 15 | (#13 AND #9) AND Language=(English
# 14 | (#12 AND #9) AND Language=(English
# 13 | (TS=( CPG* OR “best practice*” OR “professional standard*” OR “standard of care” OR (practice NEAR/2 guideline*) OR (practice NEAR/2 recommendation*) OR (practice NEAR/2 statement) OR (position NEAR/2 guideline*) OR (position NEAR/2 recommendation*) OR (position NEAR/2 statement) OR (consensus NEAR/2 guideline*) OR (consensus NEAR/2 recommendation*) OR (consensus NEAR/2 statement))) AND Language=(English)
# 12 | (#10 NOT #11) AND Language=(English)
# 11 | (TS=(animal* OR rat OR rats OR mouse OR mice OR rodent* OR rabbit OR rabbits OR horse OR horses OR equine OR veterinar* OR bovine OR cow OR cows OR pig OR pigs OR porcine)) AND Language=(English)
# 10 | ((TS=(randomized controlled trial* OR controlled clinical trial* OR research design OR placebo* OR random*) OR TS=(cohort* OR longitude* OR prospectiv* OR retrospectiv* OR long term OR long-term OR longterm OR followup OR “follow up” OR follow-up) AND TS=(study OR studies OR trial))) AND Language=(English)
# 9 | (#8 OR #4) AND Language=(English)
# 8 | (#7 AND #1) AND Language=(English)
# 7 | (#6 OR #5) AND Language=(English)
# 6 | TS= ((diet NEAR/2 therap*) OR (diet NEAR/2 restrict*) OR (diet NEAR/2 advice) OR “medical nutrition* therapy” OR MNT OR lifestyle* OR life-style* OR (“blood glucose” NEAR self-monitor*) OR (“blood glucose” NEAR “self monitor*”) OR SMBG OR counsel* OR (induc* NEAR labour) OR (induc* NEAR labor) OR cesarean OR caesarean OR (pregnan* NEAR outcome*))) AND Language=(English)
# 5 | TS= (intervention* OR treat* OR therap* OR sulfonylurea* OR antidiabet* OR anti-diabet* OR gliclazid* OR glimepirid* OR glipizid* OR glyburid* OR tolbutamid* OR antidiabet* OR anti-diabet* OR insulin* OR glibenclamid* OR acarbos*)) AND Language=(English)
# 4 | #3 AND #2 AND #1
# 3 | TS=(“sensitivity and specificity” OR sensitiv* OR specific* OR “predictive value” OR (diagnos* NEAR error*) OR “false negative” OR “false positive” OR accurac*)) AND Language=(English)
# 2 | TS=( “prenatal screen*” OR (glucose NEAR/3 tolerance) OR (glucose NEAR/3 intoleran*) OR (glucose NEAR/3 challenge*) OR OGTT OR GCT OR “fasting glucose” OR “risk factor* ”)) AND Language=(English)
# 1 | TS= ((gestation* NEAR/2 diabet*) OR (gestation* NEAR/2 “glucose intoleran*”) OR (gestation* NEAR/2 “insulin resist*”) OR (pregnan* NEAR/2 diabet*) OR (pregnan* NEAR/2 “glucose intoleran*”) OR (pregnan* NEAR/2 “insulin resist*”) OR (maternal NEAR/2 diabet*) OR (maternal NEAR/2 “glucose intoleran*”) OR (maternal NEAR/2 “insulin resist*”) OR (hyperglycemia NEAR/2 pregnan*) OR (hyperglycaemia NEAR/2 pregnan*) OR macrosomia OR GDM)) AND Language=(English)

Table A11 LILACS (Latin American and Caribbean Health Science Literature)

Database: LILACS (Latin American and Caribbean Health Science Literature) <1982–current>
Search Date: 14 October 2011
Results: 236
1. | gestational diabet$ AND (screening OR diagnos$)
2. | maternal diabet$ AND (screening OR diagnos$)
3. | gestational diabet$ AND (treating or treatment$ or therapy or therapies)
4. | maternal diabet$ AND (treating or treatment$ or therapy or therapies)

Table A12 OCLC PapersFirst and PapersFirst

Databases:
ProceedingsFirst
PapersFirst
Search Date: 16 October 2011
Results:
ProceedingsFirst: 138; PapersFirst: 102
(kw: gestation* w2 diabet* OR kw: gestation* w2 glucose w intoleran* OR kw: gestation* w2 insulin w resist* OR kw: pregnan* w2 diabet* OR kw: pregnan* w2 glucose w intoleran* OR kw: pregnan* w2 insulin w resist* OR kw: maternal w2 diabet* OR kw: maternal w2 glucose w intoleran* OR kw: maternal w2 insulin w resist* OR kw: hyperglycemia w2 pregnan* OR kw: hyperglycaemia w2 pregnan* OR kw: macrosomia OR kw: GDM) and ((kw: prenatal w screen* OR kw: glucose w3 tolerance OR kw: glucose w3 intoleran* OR kw: glucose w3 challenge* OR kw: OGTT OR kw: GCT OR kw: fasting w glucose OR kw: risk w factor*) or ((kw: intervention* OR kw: treat* OR kw: therap* OR kw: sulfonylurea* OR kw: antidiabet* OR kw: anti-diabet* OR kw: gliclazid* OR kw: glimepirid* OR kw: glipizid* OR kw: glyburid* OR kw: tolbutamid* OR kw: antidiabet* OR kw: anti-diabet* OR kw: insulin* OR kw: glibenclamid* OR kw: acarbos*) or (kw: diet w2 therap* OR kw: diet w2 restrict* OR kw: diet w2 advice OR kw: medical w nutrition* w therapy OR kw: MNT OR kw: lifestyle* OR kw: life-style* OR kw: blood w glucose w self-monitor* OR kw: blood w glucose w self w monitor* OR kw: SMBG OR kw: counsel* OR kw: induc* w labour OR kw: induc* w labor OR kw: cesarean OR kw: caesarean OR kw: pregnan* w outcome*)))

Table A13 PubMed

Database: PubMed via NLM <last 180 days from 9 October 2011>
Search Date: 9 October 2011
Results: 377
#46 #39 NOT #45 #45 animal[TI] OR rat[TI] OR rats[TI] OR mouse [TI] OR mice[TI] OR rodent*[TI] OR rabbit*[TI] OR horse*[TI] OR horses[TI] veterinar*[TI] OR cattle[TI] OR bovine[TI] OR cow[TI] OR cows[TI] OR swine[TI] OR pig[TI] OR pigs[TI] OR porcine[TI] #39 #21 OR #37 Limits: English, published in the last 180 days #38 #21 OR #37 #37 #7 and #36 #36 #22 OR #23 OR #25 OR #28 OR #30 OR #31 OR #32 OR #33 OR #34 OR #34 #35 pregnanc* outcome* #34 cesarean OR caesarean #33 ((induc* AND labour) OR (induc* AND labor)) #32 counsel* #31 SMBG #30 ((self monitor* OR self-monitor*) AND blood glucose) #28 (blood glucose AND (self monitor* OR self-monitor*)) #25 lifestyle OR life-style #24 diet therap* OR diet* restrict* OR diet* advice OR medical nutrition therapy OR MNT #23 sulfonylurea* OR gliclazid* OR glimepirid* OR glipizid* OR glyburid* OR tolbutamid* OR antidiabet* OR anti-diabet* OR insulin* OR glibenclamid* OR acarbos* #22 intervention* OR treating OR treatment? OR therapy OR therapies OR manage* OR monitor* #21 #7 AND #16 AND #20 #20 #17 OR #18 OR #19 #19 reference standard* OR reference value* #18 ROC OR “receiver operating characteristic” #17 specific* OR sensitiv* OR predictive value OR accurac* OR diagnostic error* #16 #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 #15 fasting glucose #14 OGTT OR GCT #13 (glucose AND (tolerance OR intolerance OR challenge)) #12 risk factor* #11 blood glucose #10 ((prenatal OR early) AND diagnosis) #9 screen* #8 mass screening[MeSH Terms] #7 #1 OR #2 OR #3 OR #4 OR #5 OR #6 #6 macrosomia #5 ((hyperglycaemia OR hyperglycemia) AND pregnan*) #4 (maternal AND (diabetic* OR diabete* OR DM OR glucose intoleran* OR insulin resistan*)) #3 (pregnan* AND (diabetic* OR diabete* OR DM OR glucose intoleran* OR insulin resistan*)) #2 (gestation* AND (diabetic* OR diabete* OR DM OR glucose intoleran* OR insulin resistan*)) #1 GDM

Table A14 Clinical Trials.gov and WHO

Databases:
ClinicalTrials.gov <1987 to February week 3 2012>
WHO International Clinical Trials Registry
Search Date: 23 February 2012
Results: 200
((asperger) OR (autistic disorder) OR autism OR schizophrenia OR (bipolar disorder) OR (depression) OR (bipolar disorder) OR (obsessive-compulsive) OR (post-traumatic) OR (anorexia nervosa) OR anorexia) AND (antipsychotics) AND (child OR adolescent OR pediatric OR infant) AND PDN(>1/1/1987) AND PDN(<12/31/2010)