# Acronyms and Abbreviations

ACHOIS: Australian Carbohydrate Intolerance in Pregnant Women Study
ACOG: American Congress of Obstetricians and Gynecologists
ADA: American Diabetes Association
ADIPS: Australasian Diabetes in Pregnancy Society
BMI: Body-mass index
CC: Carpenter and Coustan
CI: Confidence interval
D: Day(s)
dL: Deciliter
DM: Diabetes mellitus
Dx: Diagnosis/diagnostic
EASD: European Association for the Study of Diabetes
FPG: Fasting plasma glucose
GCT/OGCT: Glucose tolerance test and oral glucose tolerance test are synonymous
GDM: Gestational diabetes mellitus
g(s): Gram(s)
h(s): Hour(s)
HSROC: Hierarchical summary receiver operator characteristic
HAPO: Hyperglycemia and Adverse Pregnancy Outcomes Study
HbA1c: Glycated Hemoglobin, Hemoglobin A1c
IFG: Impaired fasting glucose
IGT: Impaired glucose tolerance
IGT-2: Double impaired glucose tolerance
IADPSG: International Association of the Diabetes in Pregnancy Study Groups
IQR: Inter-quartile range
IWC: International Workshop Conference
JSOG: Japan Society of Obstetrics and Gynecology
kg: kilogram
LGA: Large for gestational age
L: Liter
m: Meter
MD: Mean difference
μmol: Micromole
mg: Milligrams
mmol: Millimole
mo(s): Month(s)
NDDG: National Diabetes Data Group
NICU: Neonatal Intensive Care Unit
NOS: Newcastle-Ottawa Quality Assessment Scale
NR: Not reported
N or n: Number
NPV: Negative predictive value
OGCT: Oral glucose challenge text
OGTT: Oral glucose tolerance test
PCS: Prospective cohort study
PPV: Positive predictive value
QUADAS: Quality assessment of diagnostic accuracy studies
RCS: Retrospective cohort study
RCT(s): Randomized controlled trial(s)
RDS: Respiratory distress syndrome
RR: Risk ratio (or relative risk)
Sn: Sensitivity
Sp: Specificity
SD: Standard deviation
SGA: Small for gestational age
WHO: World Health Organization
wk(s): Week(s)
yr(s): Year(s)