# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tamara Durec (searching), Andrea Milne (searching, technical support), Teodora Radisic (article retrieval), Jocelyn Shulhan (screening), Annabritt Chisholm (research support, reference management), and Noah Toppings (development of Figure 1). We thank Dr. Alun Edwards for providing clinical input throughout the project.