# Evidence Tables

Evidence Table 1. Milk thistle for treatment of liver disease: Placebo-controlled, randomized, blinded trials

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Benda^76^ Year: 1980 Country: Germany Language: German | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon ^®^)/420 mg daily/ Unclear Control: Placebo MVI Outcome measures ^a^ : Survival Followup interval: 4 years Assessment time points with results reported: 4 years | Type: Alcoholic and nonalcoholic cirrhosis Include: Biopsy-proven cirrhosis Exclude: Moribund; poor compliance; immunosuppressive treatment in the past year; Prednisone in past 6 months; D-Penicillamine in past 3 months; primary biliary cirrhosis; Wilson's disease Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: No information | N: 172 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: + Trend: Survival Not significant: Note: Trend was assessed qualitatively only for this review.
Author: Bunout^66^ Year: 1992 Country: Chile Language: Spanish | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^)/280 mg daily/446 days Control: Placebo Outcome measures ^a^ : AST, GGTP, alk phos, bilirubin, albumin, PT Followup interval: Monthly for an average of 15 months Assessment time points with results reported: Mean of 15 months | Type: Alcoholic liver disease (inactive cirrhosis, active cirrhosis, cirrhosis with alcoholic hepatitis, alcoholic hepatitis, fibrosis) Include: Positive for alcohol history and symptoms of icterus edema, ascites, or encepholopathy or total bilirubin exceeding 2 mg/dL; PT exceeding 75 percent control; albumin less than 3 mg/dL Exclude: HBV antigen; renal failure; cardiac failure; terminal liver disease Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: Demos, LFTs appear similar | N: 59 Mean age: 50 Percent male: 86 Setting: Specialty clinic | Significant: Albumin Not significant: Child's score, bilirubin, AST, GGTP, alk phos, PT
Author: Buzelli ^79^ Year: 1993 Country: Italy Language: English | Study type: RCT/blind Intervention/dose/duration: Silipide ^®^ /240 mg silybin equivalents daily/7 days Control: Placebo Outcome measures ^a^ : AST, ALT, GGTP, MDA, alk phos, bilirubin, albumin Followup interval: 7 days Assessment time points with results reported: 7 days | Type: Chronic active hepatitis due to HBV and/or HCV Include: Biopsy-proven CAH, AST, and/or ALT greater than twice normal limits for more than 12 months; age 30 to 70 years old Exclude: Portal hypertension; hepatic encephalopathy, ascites, hepatocellular cancer, pruritus, icterus bilirubin, and alk phos more than two-fold reference values; drug addiction and ANA, AMA, and ASMA; alcohol exceeding 30 g/d; malabsorption syndromes; cardiovascular, renal, or endocrine disorders; pregnancy; any drug treatment 3 months before beginning trial Acuity/severity: Chronic, AST or ALT greater than twice normal limits Baseline group similarity: Demos, LFTs appear similar | N: 20 Mean age: 53 Percent male: 30 Setting: Hospital | Significant: AST, ALT, GGTP Not significant: Bilirubin, alk phos, MDA, albumin
Author: Feher ^70^ ^99^ ^100^ Year: 1989/1990 Country: Hungary Language: Hungarian | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/180 days Control: Placebo Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin, albumin Followup interval: 90 and 180 days Assessment time points with results reported: 90 and 180 days | Type: Chronic alcoholic liver disease (cirrhosis, reactive fibrosis, fatty degeneration) Include: Alcohol intake exceeding 60 g/d in men and 30 g/d in women for 8 ± 4 years; chronic liver disease; no previous corticosteroid or immunosuppressive treatment Exclude: Not given Acuity/severity: Chronic, no other information Baseline group similarity: Demos, LFTs appear similar | N: 36 Mean age: 46 Percent male: 75 Setting: Unclear | Significant: AST, GGTP, MDA Not significant: (Assumed for all) ALT, alk phos, albumin, PT
Author: Ferenci ^75^ Year: 1989 Country: Austria Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/ mean 41 months, range 2 to 6 years Control: Placebo Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin, albumin, PT Followup interval: 4 years Assessment time points with results reported: 2 and 4 to 5.5 years for survival | Type: Alcoholic and nonalcoholic cirrhosis; cirrhosis with alcoholic hepatitis Include: Diagnosis of cirrhosis within 2 years before entering study Exclude: End-stage liver disease; known malignancies; primary biliary cirrhosis; immunosuppressive therapy Acuity/severity: Chronic, cirrhosis, Child's score A/B/C 89/69/12 Baseline group similarity: Demos, LFTs appear similar | N: 170 Mean age: 57 Percent male: 72 Setting: Primary care/community clinic, specialty clinic, hospital | Significant: Survival (alcohol disease, Child's score A) Not significant: (No data given; reported only as not significant) AST, ALT, GGTP, bilirubin, survival (non-alcohol disease, Child's score B and C) Correspondence from Ferenci, October 10, 1999: Length of treatment was variable. All patients were treated for 2 years (original primary end point) and were continued on the same therapy until the last patient that entered completed 2 years of therapy. Mortality was 27/83 in placebo group and 20/83 in silymarin group.
Author: Fintelmann ^73^ Year: 1980 Country: Germany Language: German | Study type: RCT/blind Intervention/dose/duration: Silymarin(Legalon ^®^ )/not given/not given Control: Placebo Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin Followup interval: Days 1, 3, 7, 10, 14, 21, 28 Assessment time points with results reported: Had to read off graphs, but all followups | Type: Toxic liver disease, any etiology (usually alcohol) Include: Clinical and laboratory evidence of toxic liver damage Exclude: Not given Acuity/severity: No other information Baseline group similarity: No information except age and gender "similar" | N: 66 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: ALT, GGTP Not significant: AST, bilirubin, alk phos
Author: Kiesewetter ^80^ Year: 1977 Country: Austria Language: German | Study type: RCT/quasi Intervention/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/365 days Control: Placebo Outcome measures ^a^ : Histologic findings Followup interval: 14, 30, 60 days then every 90 days to 1 year Assessment time points with results reported: One, combined/90 to 360 days | Type: Viral hepatitis (CPH and CAH) Include: CPH or CAH for more than 6 months; other medications for liver discontinued for 2 weeks or more Exclude: Disease less than 6 months; previous treatment with silymarin, steroids, or other cytotoxic drugs; alcohol exceeding 80 g/d or exceeding alcohol intake by laboratory values than patients' statement; other comorbidities requiring medications Acuity/severity: Chronic, no other information Baseline group similarity: Demos, similar, no information on LFTs | N: 24 Mean age: 53 Percent male: 50 Setting: Hospital | Significant: + Trend: Improvement in liver biopsy Not significant: Note: Trend was assessed qualitatively only for this review.
Author: Lang ^71^ Year: 1990 Country: Hungary Language: English | Study type: RCT/blind/three arms Interventions/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/30 days AICA-P/600 mg daily/30 days Control: Placebo Outcome measures ^a^ : AST, ALT, GGTP, alk phos, albumin Followup interval: 28 days Assessment time points with results reported: Weekly for 1 month | Type: Alcoholic cirrhosis Include: Alcohol intake exceeding 60 g/d in men and 30 g/d women for more than 6 years; histologic diagnosis of micronodular cirrhosis Exclude: Vascular and/or parenchymal decompensation; +HBsAg Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: LFTs appear similar | N: 60 Mean age: 45 Percent male: 68 Setting: Unclear | Significant: AST, ALT, GGTP Not significant: Bilirubin
Author: Magliulo ^78^ Year: 1978 Country: Italy Language: German | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/25 days Control: Placebo Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin, PT Followup interval: 1, 3, 5, 7, 9, 14, 21, 28 days Assessment time points with results reported: All followup | Type: Viral HAV and HBV Include: Acute HAV and HBV patients Exclude: Not given Acuity/severity: Acute, no other information Baseline group similarity: LFTs appear similar | N: 59 Mean age: 37 Percent male: 22 Setting: Hospital | Significant: AST, bilirubin + Trend: ALT Not significant: Alk phos Note: Trend was assessed qualitatively only for this review.
Author: Palasciano ^81^ Year: 1994 Country: Italy Language: English | Study type: RCT/blind, factorial design Intervention/dose/duration: Silymarin and psychotropic drugs/800 mg silymarin daily/ 90 days Silymarin and psychotropic drugs discontinued/800 mg daily/90 days Control: Placebo and no psychotropic drugs discontinued Placebo and psychotropic drugs/ not given/90 days Outcome measures ^a^ : AST, ALT, MDA Followup interval: Day 15, 30, 60, 90, 120 Assessment time points with results reported: 30, 60, 90, and 120 days for MDA; 30 and 90 for AST and ALT | Type: Drug-induced liver disease (some patients were HBV-positive) Include: Women 40 to 60 years old; hospitalized; phenothiazines and/or butyrophenones for 5 years; AST or ALT greater than twice normal limits Exclude: Current therapy with other drugs that could influence progress of hepatopathy; other hepatopathies (alcohol, viral, autoimmune, hemochromatosis, Wilson's disease, porphyria cutanea tarda, primary or secondary hepatic neoplasia); BUN exceeding 60 mg/dL and/or creatinine exceeding 2.5 mg/dL; cardiac and circulatory insufficiency; diabetes mellitus; other important extrahepatic diseases; verified or presumed pregnancy; alcohol (more than 30 g/d) or opiate abuse Acuity/severity: Chronic; AST or ALT greater than two times the normal limit Baseline group similarity: Demos similar; LFTs variable | N: 60 Mean age: 52 Percent male: 0 Setting: Hospital | Significant: MDA for psychotropic drugs with silymarin versus placebo Not significant: AST, ALT, MDA for psychotropic drugs discontinued, silymarin versus placebo
Author: Pares ^68^ Year: 1998 Country: Spain Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon ^®^ )/450 mg daily/unclear Control: Placebo Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin, albumin, PT Followup interval: Every 3 months for 2 years Assessment time points with results reported: Survival at 5 years; all others at 2 years (assumed) | Type: Alcoholic cirrhosis (24 percent had superimposed alcohol hepatitis) Include: Chronic alcoholism defined as alcohol exceeding 80 g/d men and 60 g/d women for more than 5 years; biopsy or laparoscopic proven alcoholic cirrhosis Exclude: If ever received colchicine, malotilate, penicillamine, or corticosteroids; life expectancy less than 6 months; drug addicted or pregnant; other known etiologies for cirrhosis (i.e., HBV, autoimmunity, primary biliary cirrhosis, or cryptogenic cirrhosis) Acuity/severity: Chronic, all cirrhosis, Child's score A/B/C/ 63/114/14 Baseline group similarity: Demos, LFTs appear similar | N: 200 Mean age: 50 Percent male: 79 Setting: Diagnosis in hospital then outpatient followup. | Significant: + Trend: Encephalopathy, UGIB, survival for HCV-positive patients Not significant: AST, ALT, GGTP, PT, bilirubin, alk phos, hepatomegaly, splenomegaly, jaundice, ascites, survival Note: Trend was assessed qualitatively only for this review.
Author: Salmi ^69^ Year: 1982 Country: Finland Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/28 days Control: Placebo Outcome measures ^a^ : AST, ALT, alk phos, bilirubin, histologic findings Followup interval: Day 28 Assessment time points with results reported: 28 days | Type: Alcoholic liver disease Include: Increased AST and ALT for more than 1 month despite order to abstain from alcohol Exclude: Not given Acuity/severity: No other information Baseline group similarity: Aminotransferase levels reported as similar but lower in controls | N: 97 Mean age: 37 Percent male: 86 Setting: Hospital | Significant: AST, ALT, histology Not significant: Alk phos, bilirubin
Author: Tanasescu ^74^ Year: 1988 Country: Romania Language: English | Study type: RCT, randomization stratified by type of disease: CPH, CAH, HCV/blind Intervention/dose/duration: Silymarin (Silimarina ^®^ )/210 mg silybin equivalents daily/40 days Control: Placebo Outcome measures ^a^ : ALT, GGTP, bilirubin, alk phos, PT Followup interval: 40 days Assessment time points with results reported: 40 days | Type: CPH, CAH, hepatic cirrhosis, etiology not given Include: Diagnosis based on hepatic biopsy; clinical and laboratory data on CAH and CPH patients; some hepatic cirrhosis patients did not have hepatic biopsy; medium forms of disease; both sexes; 20 to 60 years old; basic disease from 1 to 10 years Exclude: Not given Acuity/severity: Chronic, no other information Baseline group similarity: Age, LFTs appear similar | N: 177 Mean age: 53 Percent male: 47 Setting: Hospital | Note: Trend was assessed qualitatively only for this review.
  | CAH | CPH | HCV
  Significant:
  + Trend: | | ALT
  Not significant: | ALT, GGTP, bilirubin, alk phos, PT | GGTP, bilirubin, alk phos, PT | ALT, GGTP, bilirubin, alk phos, PT
Author: Trinchet ^67^ Year: 1989 Country: France Language: French | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/90 days Control: Placebo Outcome measures ^a^ : AST, GGTP, bilirubin, albumin, PT, histology Followup interval: 90 days Assessment time points with results reported: 90 days | Type: Alcoholic hepatitis (50 percent with cirrhosis) Include: Biopsy-proven alcoholic hepatitis with or without cirrhosis Exclude: Hepatic encephalopathy; contraindications to liver biopsy; hepatocellular cancer; ascites resistant to diuretics; platelets less than 100,000 per mm; PT less than 50 percent; other diseases limiting survival Acuity/severity: 58/116 with cirrhosis; no other information Baseline group similarity: Demos, LFTs appear similar | N: 116 Mean age: 51 Percent male: 67% Setting: Unclear | Significant: Both silymarin and placebo better with alcohol abstinence Not significant: PT, albumin, bilirubin, GGTP, AST, histologic findings (hepatitis, fibrosis)

a Results not necessarily reported for all.

Alk phos = alkaline phosphatase; ALT = alanine aminotranferase; AMA = antimitochondrial antibody; ANA = antinuclear antibody;

ASMA = antismooth muscle antibody; AST = aspartase aminotranferase; BUN = blood urea nitrogen; CAH = chronic active hepatitis;

CPH = chronic persistent hepatitis; demos = demographic variables; GGTP = gammaglutamyl transpeptidase; HAV = hepatitis A virus; HbsAg = Hepatitis B surface antigen; HBV = hepatitis B virus; HCV = hepatitis C virus; LFT = liver function test; MDA = malondialdehyde; MVI = multivitamin; PT = prothrombin time;

RCT = randomized controlled trial; UGIB = upper gastrointestinal bleed.

Evidence Table 2. Milk thistle for treatment of liver disease: Placebo-controlled, prospective trials with unclear blinding

Study | Design | Liver Disease | Patient Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Fintelmann ^72^ Year: 1970 Country: Germany Language: German | Study type: Cohort with comparison group/blinding unclear Intervention/dose/duration: Silymarin (Legalon ^®^ )/6 tablets daily/42 days Control: Placebo Outcome measures ^a^ : Bilirubin, alk phos, AST, ALT Followup interval: 42 days Assessment time points with results reported: 42 days | Type: Alcoholic liver disease, also other causes of fatty liver (pure parenchymal fatty degeneration, fatty degeneration and reactive inflammation, cirrhosis transformation in progress) Include: Biopsy-proven fatty liver, including early cirrhosis without portal hypertension, assignment stratified by diabetes mellitus, obesity, alcohol intake Exclude: Not given Acuity/severity: All degrees of fatty liver including early cirrhosis without portal hypertension Baseline group similarity: LFTs appear similar | N: 50 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: AST (categorical) Not significant: AST (continuous), ALT, alk phos
Author: Marcelli ^77^ Year: 1992 Country: Italy Language: English | Study type: RCT/blinding unclear Intervention/dose/duration: Silipide ^®^)/240 mg daily/90 days Control: Placebo Outcome measures ^a^ : AST, ALT, bilirubin, albumin, PT Followup interval: 90 days Assessment time points with results reported: 90 days | Type: CPH, etiology unknown Include: Biopsy confirmed CPH, ALT, or AST 1.5 or greater than 2 times normal limits in past year Exclude: Other forms of liver disease (non-CPH) or decompensated disease; treatment with interferon antivirals, immunosuppressants, or immunomodulators within past 6 months Acuity/severity: Chronic, no other information Baseline group similarity: Demos appear similar; higher AST and ALT in Silipide ^®^ group | N: 65 Mean age: 48 Percent male: 71 Setting: Specialty clinic | Significant: AST, ALT Not significant: Bilirubin, albumin, PT

a Results not necessarily reported for all.

alk phos = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartase aminotransferase; CPH = chronic persistent hepatitis; Demos = demographic variables; LFT = liver function test; PT = prothrombin time; RCT = randomized controlled trial.

Evidence Table 3. Milk thistle for treatment of liver disease: Studies without placebo controls

Study | Design | Liver Disease | Patient Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Boari^101^ Year: 1981 Country: Italy Language: Italian | Study type: RCT unclear/blinding unclear Intervention/dose/duration: Silymarin/420 mg daily/15 to 20 days Control: Vitamin B complex/not given/15 to 20 days Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin Followup interval: 20 days Assessment time points with results reported: 20 days | Type: Toxic hepatopathy caused by various substances (mostly solvents, paints, and glues); mostly suffering from chronic or subacute forms Include: Not given Exclude: Not given Acuity/severity: ? Chronic, 0 cirrhosis, 11 liver failure, 29 other, no other information | N: 55 Mean age: 36 Percent male: 60 Setting: Hospital | Significant: AST, ALT, GGTP, alk phos Not significant: Bilirubin
Author: Bode^102^ Year: 1977 Country: Germany Language: German | Study type: RCT (quasi/odd-even birthdate)/not blind Intervention/dose/duration: Silymarin (Legalon^®^)/420 mg daily/35 days Control: No treatment Outcome measures^a^: AST, ALT, GGTP, alk phos, bilirubin, PT Followup interval: 10, 25, 35 days Assessment time points with results reported: 35 days | Type: Viral hepatitis Include: Patients with viral hepatitis Exclude: Jaundice exceeding 8 days Acuity/severity: Acute, no other information | N: 151 Mean age: Not given Percent male: 48 Setting: Unclear | Significant: Not Significant: AST, bilirubin, ALT, alk phos
Author: Cavalieri ^103^ Year: 1974 Country: Italy Language: Italian | Study Type: RCT unclear/blinding unclear Intervention/dose/duration: Silymarin (Legalon ^®^ )/ 420 mg daily/variable Control: "Traditional treatment": a 12-component cocktail including vitamin and steroids Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin, PT Followup interval: 7, 14, 28 days Assessment time points with results reported: 7, 14, 28 days | Type: Acute hepatitis (posttransfusion, contagious, presumably parenteral, and sporadic) Include: Not given Exclude: Not given Acuity/severity: Acute, no other information | N: 40 Mean age: 29 Percent male: 45 Setting: Hospital | Significant: AST at weeks 1, 2, and 3; ALT at week 2; alk phos at week 1; albumin at week 1 Not Significant: AST at week 4; ALT at weeks 1, 3, and 4; PT and albumin at weeks 2 and 3
Author: Del Dotto ^104^ Year: 1982 Country: Italy Language: Italian | Study Type: RCT unclear/blinding unclear Intervention/dose/duration: Silymarin (Legalon ^®^ )/420 mg daily/90 days Control: Vitamin B complex Outcome measures ^a^ : AST, ALT, GGTP, PT, bilirubin, albumin, alk phos Followup interval: 30, 60, 90 days Assessment time points with results reported: 30, 60, 90 days | Type: Alcoholic liver disease Include: Patients with alcoholic liver disease Exclude: Not given Acuity/severity: Chronic, no other information | N: 42 Mean age: 53 Percent male: 74 Setting: Specialty clinic | Significant: Not Significant: AST, ALT, GGTP, PT, bilirubin, albumin, alk phos
Author: DeMartiis ^105^ Year: 1980 Country: Italy Language: Italian | Study Type: RCT unclear/blinding unclear Intervention/dose/duration: Silymarin, traditional therapy, and diet/400 mg daily/45 to 90 days Control: Traditional therapy + diet Outcome measures ^a^ : Bilirubin Followup interval: 90 days Assessment time points with results reported: 90 days | Type: Chronic hepatitis and cirrhosis Include: Macrocytic anemia and hemolytic syndrome Exclude: Lab values indicating the presence of cholestasis (alk phos, GGTP) dyslipidemia, or diabetes Acuity/severity: Chronic, no other information | .5pt; padding:0in 1.45pt 0in 1.45pt;height:139.0pt'>N: 45 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: Not Significant: Indirect bilirubin
Author: DeMartiis^106^ Year: 1980 Country: Italy Language: Italian | Study Type: RCT unclear/blinding unclear Intervention/dose/duration: Vitamin B12, folic acid, uridin-5, difosfoglucose, and silymarin/ 600 mg daily/not given Vitamin B12, folic acid, uridin-5, and difosfoglucose/not given/not given Control: Vitamin B12, folic acid, uridin-5, and difosfoglucose/not given/not given Outcome measures ^a^ : Alk phos, bilirubin Followup interval: Unclear Assessment time points with results reported: Unclear | Type: Chronic hepatopathies (diagnoses include chronic hepatitis, hepatic cirrhosis, and hepatic neoplasm) Include: Hepatic disease Exclude: Not given Acuity/severity: 0 acute, 21 chronic, 61 cirrhosis, no other information | N: 91 Mean age: 56 Percent male: 71 Setting: Not given
  | All Patients | CE or EC | CE | EC
  Significant: | Alk phos | Alk phos, bilirubin | Bilirubin, alk phos
  Not significant: | All others | All others | | All
Author: Fintelmann ^107^ Year: 1973 Country: Germany Language: German | Study Type: RCT unclear/blinding unclear Intervention/dose/duration: Silymarin (Legalon ^®^ )/210 or 420 mg daily/preoperative and 8 days postoperative Control: No treatment Outcome measures ^a^ : AST, ALT, alk phos, bilirubin Followup interval: 1, 2, 3 days Assessment time points with results reported: 1, 2, 3 days | Type: Cholestasis, not pregnancy related Include: Consecutive patients for cholecystectomy with cholelithiasis with or without cholecystitis Exclude: Obstructive jaundice Acuity/severity: Acute, no other information | N: 63 Mean age: Not given Percent male: 6 Setting: Hospital | Significant: + Trend: Less increase in AST, ALT on postoperative day 1 Not Significant: AST, ALT, bilirubin, alk phos Note: Trend was assessed qualitatively only for this review.
Author: Flisiak ^65^ Year: 1997 Country: Poland Language: English | Study Type: RCT/not blind Intervention/dose/duration: Silymarin/210 mg daily/28 days Control: Misoprostol Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin, jaundice, hepatomegaly Followup interval: 7, 14, 21, 28 days Assessment time points with results reported: 7, 14, 21, 28 days | Type: Viral HBV Include: Viral HBV by HBsAg detection; male patients admitted; endoscopically confirmed stomach mucosal injury; comparable age and duration of jaundice (approximately 2 to 9 days); severe hepatocellular dysfunction with marked increases in bilirubin, AST, and ALT Exclude: Female patients; concomitant alcoholism, HCV or HDV infections and chronic diseases (e.g., diabetes) Acuity/severity: Acute | N: 52 Mean age: 46 Percent male: 100 Setting: Hospital | Significant: Misoprostol better than silymarin for hepatomegaly bilirubin, alk phos Not Significant: GGTP, AST, ALT Correspondence from Flisiak, November 2,1999: Study was not placebo controlled; subjects were blinded, but providers and outcome assessors were not blinded
Author: Flisiak ^65^ Year: 1997 Country: Poland Language: English | Study Type: Cohort with comparison group/not blind Intervention/dose/duration: Silymarin/210 mg daily/28 days Control: No treatment Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin, jaundice, hepatomegaly Followup interval: 7, 14, 21, 28 days Assessment time points with results reported: 7, 14, 21, 28 days | Type: Viral HBV Include: Viral HBV by HBsAg; male patients admitted; endoscopically confirmed stomach mucosal injury; comparable age and duration of jaundice (approximately 2 to 9 days), severe hepatocellular dysfunction with marked increases in bilirubin, AST, and ALT Exclude: Female patients, concomitant alcoholism, HCV or HDV infections and chronic disease (e.g., diabetes) Acuity/severity: Acute, no other information | N: 52 Mean age: 46 Percent male: 100 Setting: Hospital | Significant: Alk phos Not Significant: AST, ALT, GGTP, bilirubin, hepatomegaly Correspondence from Flisiak, November 2, 1999: Study was not placebo controlled; subjects were blinded, but providers and outcome assessors were not blinded
Author: Lirussi ^108^ Year: 1995 Country: Italy Language: English | Study Type: RCT/blinding unclear Intervention/dose/duration: UDCA/600 mg daily/180 days Silymarin (Legalon ^®^ )/420 mg/180 days Combination therapy UDCA and silymarin/600 mg UDCA and 420 mg silymarin/6 months Outcome measures ^a^ : AST, ALT GGTP, alk phos, bilirubin Followup interval: 90, 180, 210, 300, 395 days Assessment time points with results reported: 90, 180 days | Type: Compensated active cirrhosis (HCV, alcoholic with or without HCV, HBsAg) Include: Biopsy-proven compensated cirrhosis; AST and ALT 2 to 10 times normal limits Exclude: Not given Acuity/severity: No other information | N: 23 Mean age: 58 Percent male: 36 Setting: Unclear Phase 1: Cross-over Phase 2: UDCA and silymarin versus no treatment | Significant: Not Significant: AST, ALT, GGTP, bilirubin, alk phos
Author: Roveda ^109^ Year: 1991 Country: Italy Language: Italian | Study Type: RCT unclear/blinding unclear Intervention/dose/duration: Silymarin/140 or 280 mg daily or silybin/70 or 140 mg daily/90 days Outcome measures ^a^ : AST, ALT, GGTP, alk phos, bilirubin Followup interval: 90 days Assessment time points with results reported: 90 days | Type: Organic and functional diseases of liver parenchyma Include: Not given Exclude: Not given Acuity/severity: No other information | N: 51 Mean age: 55 Percent male: 41 Setting: Not given | Significant: Not Significant: Hepatomegaly, gastric burning, pain on palpation
Author: Saba ^110^ Year: 1979 Country: Italy Language: Italian | Study Type: RCT/blinding unclear Intervention/dose/duration: Silymarin/420 mg daily/not given Control: MVI + choline + methionin Outcome measures ^a^ : AST, ALT, alk phos, bilirubin Followup interval: Unclear Assessment time points with results reported: Unclear | Type: Acute viral hepatitis Include: Onset in 15 days or fewer; hospitalized 4 days or fewer of onset of jaundice; no previous episodes of jaundice Exclude: More than 100 g of alcohol per day for 15 days or fewer of disease onset Acuity/severity: Acute, no other information | N: 38 Mean age: 36 Percent male: 53 Setting: Not given | Significant: Time to normalization for direct bilirubin, AST, ALT, alk phos Not Significant: Time to normalization for total bilirubin
Author: Schopen ^111^ Year: 1970 Country: Germany Language: German | Study Type: RCT/blinding unclear Intervention/dose/duration: Silymarin (Legalon ^®^ )/1 tablet = 35 mg (dose varied from 6 tablets daily to 9 tablets daily and, in rare cases, 12 tablets daily/mean 45 days Control: Other hepatoprotective medicines but not silymarin Outcome measures ^a^ : AST, ALT, alk phos, bilirubin, albumin, PT Followup interval: 45 days Assessment time points with results reported: Mean 45 days | Type: Alcoholic-, toxin-, and drug-induced liver disease and fatty liver secondary to diabetes mellitus; cholestasis (not pregnancy related) Include: Patients with microscopic changes of moderately severe to severe localized fatty deposits or diffuse steatosis; 51 toxic metabolic changes with fatty liver and some with cholestasis (patients with alcohol abuse, some diabetes mellitus); 13 diabetes mellitus; 8 poisoning; 2 aflatoxin; 1 mercury; 5 chronic barbiturate abuse Exclude: Not given Acuity/severity: No other information | N: 72 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: AST, ALT Not Significant:
Author: Szilard ^112^ Year: 1988 Country: Hungary Language: English | Study Type: Cohort/not blind Intervention/dose/duration: Silymarin (Legalon ^®^ ) 420 mg daily/30 days Control: No treatment Outcome measures ^a^ : AST, ALT, GGTP Followup interval: 30 days Assessment time points with results reported: 28 days | Type: Toxic hepatopathy caused by organic solvents (toluene and xylene) Include: Hepatomegaly, increased AST and ALT levels, lymphocytosis, decreased platelet counts attributable to toluene and/or xylene Exlcude: Alcoholics Acuity/severity: No other information Baseline group similarity: Demos, LFTs, appear similar except higher GGTP in treatment group | N: 49 (Legalon ^®^ = 30; no treatment = 19) Mean age: Not given Percent male: 100 Setting: Workplace | Significant: AST, ALT Not Significant: GGTP
Author: Tkacz ^113^ Year: 1983 Country: Poland Language: Polish | Study Type: RCT unclear/blinding unclear Intervention/dose/duration: Silimarol ^®^ (and vitamins B and C)/6 pills daily/21 days Control: Vitamins B and C and cocarboxylase Outcome measures ^a^ : ALT, alk phos, bilirubin, PT Followup interval: 21 days Assessment time points with results reported: 21 days | Type: Viral hepatitis Include: Abnormal LFTs Exclude: Not given Acuity/severity: No other information | N: 87 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: Not Significant: ALT, PT, bilirubin, length of stay
Author: Vailati ^85^ Year: 1993 Country: Italy Language: English | Study Type: RCT/not blind/phase 2 study Intervention/dose/duration: Silymarin (Silipide ^®^ )/160 mg silybin equivalents daily/14 days Silymarin (Silipide ^®^ )/240 mg silybin equivalents daily/14days Silymarin (Silipide ^®^ )/360 mg silybin equivalents daily/14 days Control: No treatment Outcome measures ^a^ : AST, GGTP, bilirubin Followup interval: 7, 14 days Assessment time points with results reported: 7, 14 days | Type: Viral and alcoholic hepatitis Include: Biopsy-proven chronic hepatitis (viral or alcoholic); AST and ALT 1.5 or greater than 2 times normal limits and biopsy within 1 year Exclude: Other forms of liver disease; decompensated liver disease; treatment with interferon, antivirals, immunosuppressants, or immunodulators for 6 months or fewer Acuity/severity: Chronic, no other information | N: 60 Mean age: 50 Percent male: 62 Setting: Outpatient clinic | Significant: AST, GGTP, bilirubin for 240 or 360 mg versus 160 mg Not Significant:
Author: Velussi ^114^ ^115^ Year: 1993, 1997 Country: Italy Language: English | Study Type: RCT/not blind Intervention/dose/duration: Silymarin (Legalon ^®^ )/600 mg daily/365 days Control: No treatment Outcome measures ^a^ : MDA, AST, ALT GGTP, alk phos, bilirubin Followup interval: 90, 180, 270, 365 days Assessment time points with results reported: 90, 180, 270, 365 days | Type: Diabetics with alcoholic cirrhosis Include: Age 45 to 70 years; NIDDM with alcoholic liver cirrhosis; BMI more than 29 kg/m^2^; diabetes for 5 or more years treated with insulin only; stable insulin therapy for 2 or more years; increased endogenous insulin secretion; negative for HAV, HBV, and HCV; not addicted to alcohol for 2 or more years before study; no variceal esophagus bleeding; positive liver biopsy for cirrhosis 4 or fewer years before enrollment Exclude: Not given Acuity/severity: Chronic, no other information | N: 60 Mean age: Not given Percent male: Not given Setting: Specialty clinic | Significant: MDA Not Significant: GGTP, bilirubin, alk phos

a Results not necessarily reported for all.

alk phos = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartase aminotransferase; BMI = body mass index; CE = cirrosi epatica;

Demos = demographic variables; EC = epatite cronica; GGTP = gammaglutamyl transpeptidase; HAV = hepatitis A virus; HbsAg = hepatitis B surface antigen;

HBV = hepatitis B virus; HCV = hepatitis C virus; HDV = hepatitis D virus; LFT = liver function test; MDA = malondialdehyde; MVI = multivitamin;

NIDDM = noninsulin dependent diabetes; PT = prothrombin time; RCT = randomized controlled trial; UDCA = ursodeoxycholic acid.

Evidence Table 4. Milk thistle for prophylaxis against liver disease: Ineligible (normal liver function at study entry) but provocative studies

Author | Design | Liver Disease | Patient Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Allain ^83^ Year: 1999 Country: France Language: English | Study type: RCT/blind/prophylaxis Intervention/dose/duration: Silymarin/420 mg daily/84 days Control: Placebo Outcome measures^a^: AST, ALT Followup interval: 8 times over 15 weeks Assessment time points with results reported: 8 times over 15 weeks | Type: Drug- (Tacrine-)induced liver disease Include: Patient over 50 years old; mild to moderate Alzheimer's disease; Tacrine treatment Exclude: Past history hepatic disorder (cirrhosis, increased bilirubin, AST, and/or ALT) Acuity/severity: No disease at baseline | N: 222 Mean age: Approximately 74 Percent male: 39 Setting: Specialty clinic | Significant: Not significant: AST, ALT
Author: Magula ^82^ Year: 1996 Country: Language: Slovak | Study type: RCT/not blinded/prophylaxis Intervention/dose/duration: Tuberculosis treatment and Hepabene^®^ (Silymarin and Fumaria officinalis alkaloids)/2 capsules daily/8 weeks Control: Tuberculosis medications alone Outcome measures^a^: AST, ALT, bilirubin, "liver injury," interruption of tuberculosis medications Followup interval: Every 2 weeks for 8 weeks Assessment time points with results reported: 8 weeks (56 days) | Type: Drug-induced liver disease Include: Patients requiring tuberculosis treatment; normal LFTs at baseline Exclude: Not given Acuity/severity: No disease at baseline | N: 172 (92 tuberculosis medications alone; 29 tuberculosis medications plus silymarin) Mean age: 50 Percent male: 60 Setting: Unclear | Significant: AST, ALT Not significant:

a Results not necessarily reported for all.

ALT = alanine aminotransferase; AST = aspartase aminotransferase; LFT = liver function test; RCT = randomized controlled trial.

Evidence Table 5. Milk thistle for treatment of liver disease: Adverse effects

Author, Year | Adverse Effect | Study N | Study Design | Milk Thistle Exposure | | Questions
Author, Year | Adverse Effect | Study N | Study Design | Type | Amount | Improved after discontinued? | Rechallenged? | Alternative causes possible? | Dose-response?
Bunout, 1992^66^ | Control: Pruritus Headache Treatment: Pruritus Headache | 11/34 4/34 4/25 3/24 | RCT | Placebo Silymarin (Legalon^®^) | 280 mg/d | Yes, in one patient Not discontinued | No No | Not given Not given | Not given Not given
Ferenci, 1989 ^75^ | Control: Nausea, epigastric discomfort Treatment: Nausea, epigastric discomfort | 2/83 2/87 | RCT | Placebo Silymarin (Legalon^®^) | 420 mg/d | Yes Yes | No No | Not given Not given | Not given Not given
Pares, 1998 ^68^ | Control: 4 Urticaria, pruritus, arthralgia, headache Treatment:7 Urticaria, pruritus, arthralgia, headache | Total n: 11/200 | RCT | Placebo Silymarin (Legalon^®^) | 450 mg/d | Yes, 2 patients in treatment and 1 patient in control | No | Not given | Not given
Vailati, 1993^85^ | Treatment: Nausea, heartburn Dyspepsia Postprandial nausea, meteorism | 3/20 1/20 2/20 | RCT | Silipide^®^ Silipide^®^ | 160 mg/d 240 mg/d 360mg/d | Yes Yes | No No | Not given Not given | Not given Not given Not given
Andrade, 1998 ^87^ | Control: Treatment: Impotence | 0/31 1/29 | RCT | Silymarin | 450 mg/d | Not given | Not given | Not given | Not given
Marcelli, 1992 ^77^ | Control: Nausea, dyspepsia, heartburn, skin rash Treatment: Nausea, heartburn, transient headache | 5/34 3/31 | RCT | Placebo Silipide^®^ | 240 mg/d | Not discontinued | Not given | Not given | Not given
Allain, 1999 ^83^ | Control: Frequency ADE occurred ^b^ : Diarrhea 5 (10.1%) Vomiting 10 (8.2%) Nausea 10 (6.3%) Anorexia 7 (5.7%) Irritability 6 (5.1%) Insomnia 6 (4.4%) Asthenia 5 (3.8%) Malaise 3 (3.2%) Bronchitis 7 (5.1%) Treatment: Frequency ADE occurred ^b^ : Diarrhea 8 (8.1%) Vomiting 6(4.8%) Nausea 10 (10.5%) Anorexia 9 (8.2%) Irritability 5 (4.8%) Insomnia 5 (4.8%) Bronchitis 7 (5.6%) | 112 110 | RCT | Placebo and Tacrine Silymarin and Tacrine | 420 mg/d | Not given Not given | Not given Not given | Not given Not given | Not given Not given
Studlar, 1985 ^90^ | Temporary uneasiness of stomach | 2/34 | Prospective cohort | Silibene^®^ (a silymarin-containing drug) | 280 mg/d | Not discontinued | Not given | Not given | Not given
Albrecht, ^a^ 1992 ^88^ | Treatment: (in 0.8% of patients): Mild diarrhea Nausea Upset stomach Itching Exanthem Headache Decreased energy and discomfort NOS | 4/2,637 3/2,637 2/2,637 2/2,637 1/2,637 1/2,637 7/2,637 | Prospective cohort | Silymarin (Legalon^®^ ) 70 mg | 3.8±1.48 tablets per day 267.4±103.6 mg 1 to 9 tablets 55.2 percent 1 tablet tid 28.3 percent 2 tablets tid | Not given | Not given | Not given | Not given
Marena, 1991 ^93^ | Gastrointestinal: Mostly upset stomach Control: Silipide^®^ | 6/117 12/232 | Cohort ^c^ | Placebo Commercial extract Silipide^®^ | 280 to 420 mg/d | Not given | Not given | Not given | Not given
Grungreiff, 1995 ^89^ | Frequency ADE occurred ^b^ : Changes in BM 4 Diarrhea 4 Dizziness/circulatory problems 4 Nausea/vomiting 2 Itching 2 Eczemas 2 Indisposition 1 Flatulence 1 | 16/975 (12 patients reported 1 adverse effect and 4 patients reported 2 adverse effects) | Cohort ^c^ | Silymarin | 280 to 420 mg/d | Not given | Not given | Not given | Not given
Frerick, ^a^ 1990^91^ | Frequency ADE occurred ^b^ : Mild diarrhea 4 Nausea 3 Gastric intolerance 2 Itching 2 Eczema 1 Diffuse headaches 1 Decreased energy/ restlessness 1 No specifics 7 | 2,169 | Cohort ^c^ | Silymarin | 1,210 patients received 210 mg/d 583 patients received 420 mg/d 376 patients received 70 to 630 mg/d | Not given | Not given | Not given | Not given
Schuppan, 1998 ^92^ | 12 ADEs occurred, but not specifically noted; examples were diarrhea, flatulence, abdominal fullness or pain, nausea, vomiting, and dizziness | 20/998 | Cohort ^c^ | Silymarin | 280 to 420 mg/d | Not given | Not given | Not given | Not given
Anonymous, 1972 ^98^ | Sweating, nausea, colicky abdominal pain, fluid diarrhea, weakness, and collapse | 1 | Case report | Microgenics Herbals M.T. Vegicaps^®^ | 1 capsule | Yes | Yes | Yes, due to multiherbal capsule | Not given
Geier, 1990 ^94^ | Anaphylactic shock: facial edema, oral mucosa swelling, marked respiratory distress, bronchospasm, and decrease blood pressure | 1 | Case report | Silybum marianum tea | Not given | Not given | Not given | Not given | Not given
Mironets, 1990 ^95^ | Urticaria, fever, laryngeal edema | 1 | Case report | Carsil^®^ | 3 pills per day, no dosage given | Yes, and Tx Prednisone | No | Not given | Not given
Wollemann, 1987 ^97^ | Rhinoconjunctivitis | 1 | Case report | Silybum marianum | Contact with seeds | Not given | Yes | Not given | Not given
DeSmet, 1996^96^ | Jaundice, increase LFTs | 1 | Case report | Multiherbal tablets with unknown amount of milk thistle | 6 to 15 tablets per day | Yes | Yes | Yes, due to multiherbal tablet | Not given

a The study by Albrecht is an extension of the study by Frerick and includes the same patients.^19^

b Unit of reporting was ADE, not patient.

c Unclear if cohort was prospective or retrospective.

ADE = adverse drug effects; BM = bowel movement; LFT = liver function test; NOS = not otherwise specified; RCT = randomized controlled trial; tid = three times daily.