# Summary Tables

Summary Table 1. Placebo-controlled studies of milk thistle for chronic alcoholic liver disease (n = 6)

Summary Table 1. Placebo-controlled studies of milk thistle for chronic alcoholic liver disease (n = 6)

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Bunout ^66^ Year: 1992 Country: Chile Language: Spanish | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^ )/280 mg daily/446 days Control: Placebo Outcome measures^a^: AST, GGTP, alk phos, bilirubin, albumin, PT Followup interval: Monthly for an average of 15 months Assessment time points with results reported: Mean of 15 months | Type: Alcoholic liver disease (inactive cirrhosis, active cirrhosis, cirrhosis with alcoholic hepatitis, alcoholic hepatitis, fibrosis) Include: Positive for alcohol history and symptoms of icterus edema, ascites, or encepholopathy or bilirubin exceeding 2 mg/dL; PT exceeding 75 percent control; albumin less than 3 mg/dL Exclude: HBV antigen; renal failure; cardiac failure; terminal liver disease Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: Demos, LFTs appear similar | N: 59 Mean age: 50 Percent male: 86 Setting: Specialty clinic | Significant: Albumin Not significant: Child's score, bilirubin, AST, GGTP, alk phos, PT, survival
Author: Feher^70^, ^99^, ^100^ Year: 1989/1990 Country: Hungary Language: Hungarian | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^ )/420 mg daily/180 days Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, bilirubin, albumin Followup interval: 90 and 180 days Assessment time points with results reported: 90 and 180 days | Type: Chronic alcoholic liver disease (cirrhosis, reactive fibrosis, fatty degeneration) Include: Alcohol intake exceeding 60 g/d in men and 30 g/d in women for 8 ± 4 years; chronic liver disease; no previous corticosteroid or immunosuppressive treatment Exclude: Not given Acuity/severity: Chronic, no other information Baseline group similarity: Demos, LFTs appear similar | N: 36 Mean age: 46 Percent male: 75 Setting: Unclear | Significant: AST, GGTP, MDA Not significant: (assumed for all) ALT, alk phos, albumin, PT, survival
Author: Lang^71^ Year: 1990 Country: Hungary Language: English | Study type: RCT/blind/three arms Interventions/dose/duration: Silymarin (Legalon^®^)/420 mg daily/30 days AICA-P/600 mg daily/30 days Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, albumin Followup interval: 28 days Assessment time points with results reported: Weekly for 1 month | Type: Alcoholic cirrhosis Include: Alcohol intake exceeding 60 g/d in men and 30 g/d women for more than 6 years; histologic diagnosis of micronodular cirrhosis Exclude: Vascular and/or parenchymal decompensation; +HBsAg Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: LFTs appear similar | N: 60 Mean age: 45 Percent male: 68 Setting: Unclear | Significant: AST, ALT, GGTP Not significant: Bilirubin
Author: Pares^68^ Year: 1998 Country: Spain Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^ )/450 mg daily/unclear Control: Placebo Outcome measures^a^ AST, ALT, GGTP, alk phos, bilirubin, albumin, PT Followup interval: Every 3 months for 2 years Assessment time points with results reported: Survival at 5 years; all others at 2 years (assumed) | Type: Alcoholic cirrhosis (24 percent had superimposed alcohol hepatitis) Include: Chronic alcoholism defined as alcohol exceeding 80 g/d men and 60 g/d women for more than 5 years; biopsy or laparoscopic proven alcoholic cirrhosis Exclude: If ever received colchicine, malotilate, penicillamine, or corticosteroids; life expectancy less than 6 months; drug addicted or pregnant; other known etiologies for cirrhosis (i.e., HBV, autoimmunity, primary biliary cirrhosis, or cryptogenic cirrhosis) Acuity/severity: Chronic, all cirrhosis, Child's score A/B/C/ 63/114/14 Baseline group similarity: Demos, LFTs appear similar | N: 200 Mean age: 50 Percent male: 79 Setting: Diagnosis in hospital then outpatient followup. | Significant: + Trend: Encephalopathy, UGIB, survival for HCV-positive patients Not significant: AST, ALT, GGTP, PT, bilirubin, alk phos, hepatomegaly, splenomegaly, jaundice, ascites, survival Note: Trend was assessed qualitatively only for this review.
Author: Salmi^69^ Year: 1982 Country: Finland Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^ )/420 mg daily/28 days Control: Placebo Outcome measures^a^: AST, ALT, alk phos, bilirubin, histology Followup interval: Day 28 Assessment time points with results reported: 28 days | Type: Alcoholic liver disease Include: Increased AST and ALT for more than 1 month despite order to abstain from alcohol Exclude: Not given Acuity/severity: No other information Baseline group similarity: Aminotransferase levels reported as similar but lower in controls | N: 97 Mean age: 37 Percent male: 86 Setting: Hospital | Significant: AST, ALT, histology Not significant: Alk phos, bilirubin
Author: Trinchet^67^ Year: 1989 Country: France Language: French | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^)/420 mg daily/ 90 days Control: Placebo Outcome measures^a^: AST, GGTP, bilirubin, albumin, PT, histology Followup interval: 90 days Assessment time points with results reported: 90 days | Type: Alcoholic hepatitis (50 percent with cirrhosis) Include: Biopsy-proven alcoholic hepatitis with or without cirrhosis Exclude: Hepatic encephalopathy; contraindications to liver biopsy; hepatocellular cancer; ascites resistant to diuretics; platelets less than 100,000 per mm; PT less than 50 percent; other diseases limiting survival Acuity/severity: 58/116 with cirrhosis; no other information Baseline group similarity: Demos, LFTs appear similar | N: 116 Mean age: 51 Percent male: 67% Setting: Unclear | Significant: Both silymarin and placebo better with alcohol abstinence Not significant: PT, albumin, bilirubin, GGTP, AST, histology (hepatitis, fibrosis)

a Results not necessarily reported for all.

Abbreviations Used: AICA-P = amino imidazol carboxamial phosphate; alk phos = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartase aminotransferase; demos = demographic variables; GGTP = gammaglutamyl transpeptidase; HbsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCV = hepatitis C virus; LFT = liver function test; MDA = malondialdehyde; PT = prothrombin time; RCT = randomized controlled trial; UGIB = upper gastrointestinal bleed.

Summary Table 2. Placebo-controlled studies of milk thistle for chronic liver disease, mixed etiologies (n = 6)

Summary Table 2. Placebo-controlled studies of milk thistle for chronic liver disease, mixed etiologies (n = 6)

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Fintelmann^73^ Year: 1980 Country: Germany Language: German | Study type: RCT/blind Intervention/dose/duration: Silymarin(Legalon^®^ )/not given/not given Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, bilirubin Followup interval: Days 1, 3, 7, 10, 14, 21, 28 Assessment time points with results reported: Had to read off graphs, but all followups | Type: Toxic liver disease, any etiology (usually alcohol) Include: Clinical and laboratory evidence of toxic liver damage Exclude: Not given Acuity/severity: No other information Baseline group similarity: No information except age and gender "similar" | N: 66 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: ALT, GGTP Not significant: AST, bilirubin, alk phos
Author: Fintelmann^72^ Year: 1970 Country: Germany Language: German | Study type: Cohort with comparison group/blinding unclear Intervention/dose/duration: Silymarin (Legalon^®^ )/6 tablets daily/42 days Control: Placebo Outcome measures^a^: Bilirubin, alk phos, AST, ALT Followup interval: 42 days Assessment time points with results reported: 42 days | Type: Alcoholic liver disease, also other causes of fatty liver (pure parenchymal fatty degeneration, fatty degeneration and reactive inflammation, cirrhosis transformation in progress) Include: Biopsy-proven fatty liver, including early cirrhosis without portal hypertension, assignment stratified by diabetes mellitus, obesity, alcohol intake Exclude: Not given Acuity/severity: All degrees of fatty liver including early cirrhosis without portal hypertension Baseline group similarity: LFTs appear similar | N: 50 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: AST (categorical) Not significant: AST (continuous), ALT, alk phos
Author: Tanasescu^74^ Year: 1988 Country: Romania Language: English | Study type: RCT, randomization stratified by type of disease: CPH, CAH, HCV/blind Intervention/dose/duration: Silymarin (Silimarina^®^)/210 mg silybin equivalents daily/ 40 days Control: Placebo Outcome measures^a^: ALT, GGTP, bilirubin, alk phos, PT Followup interval: 40 days Assessment time points with results reported: 40 days | Type: CPH, CAH, hepatic cirrhosis, etiology not given Include: Diagnosis based on hepatic biopsy; clinical and laboratory data on CAH and CPH patients; some hepatic cirrhosis patients did not have hepatic biopsy; medium forms of disease; both sexes; 20 to 60 years old; basic disease from 1 to 10 years Exclude: Not given Acuity/severity: Chronic, no other information Baseline group similarity: Age, LFTs appear similar | N: 177 Mean age: 53 Percent male: 47 Setting: Hospital | Note: Trend was assessed qualitatively only for this review.
  | CAH | CPH | HCV
  Significant:
  + Trend: | | ALT
  Not significant: | ALT, GGTP, bilirubin, alk phos, PT | GGTP, bilirubin, alk phos, PT | ALT, GGTP, bilirubin, alk phos, PT
Author: Ferenci^75^ Year: 1989 Country: Austria Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^ )/420 mg daily/ mean 41 months, range 2 to 6 years Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, bilirubin, albumin, PT Followup interval: 4 years Assessment time points with results reported: 2 and 4 to 5.5 years for survival | Type: Alcoholic and nonalcoholic cirrhosis; cirrhosis with alcoholic hepatitis Include: Diagnosis of cirrhosis within 2 years before entering study Exclude: End-stage liver disease; known malignancies; primary biliary cirrhosis; immunosuppressive therapy Acuity/severity: Chronic, cirrhosis, Child's score A/B/C 89/69/12 Baseline group similarity: Demos, LFTs appear similar | N: 170 Mean age: 57 Percent male: 72 Setting: Primary care/community clinic, specialty clinic, hospital | Significant: Survival (alcohol disease, Child's score A) Not significant: (No data given; reported only as not significant) AST, ALT, GGTP, bilirubin, survival (nonalcohol disease, Child's score B and C) Correspondence from Ferenci, Oct. 10, 1999: Length of treatment was variable. All patients were treated for 2 years (original primary endpoint) and were continued on the same therapy until the last patient that entered completed 2 years of therapy. Mortality was 27/83 in placebo group and 20/83 in silymarin group.
Author: Benda ^76^ Year: 1980 Country: Germany Language: German | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^)/420 mg daily/ Unclear Control: Placebo MVI Outcome measures^a^: Survival Followup interval: 4 years Assessment time points with results reported: 4 years | Type: Alcoholic and nonalcoholic cirrhosis Include:Biopsy-proven cirrhosis Exclude: Moribund; poor compliance; immunosuppressive treatment in the past year; prednisone in past 6 months; D-penicillamine in past 3 months; primary biliary cirrhosis; Wilson's disease Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: No information | N: 172 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: + Trend: Survival Not significant: Note: Trend was assessed qualitatively only for this review.
Author: Marcelli^77^ Year: 1992 Country: Italy Language: English | Study type: RCT/blinding unclear Intervention/dose/duration: Silipide^®^/240 mg daily/90 days Control: Placebo Outcome measures^a^: AST, ALT, bilirubin, albumin, PT Followup interval: 90 days Assessment time points with results reported: 90 days | Type: CPH, etiology unknown Include: Biopsy confirmed CPH, ALT, or AST 1.5 or greater than 2 times normal limits in past year Exclude: Other forms of liver disease (non-CPH) or decompensated disease; treatment with interferon antivirals, immunosuppressants, or immunomodulators within past 6 months Acuity/severity: Chronic, no other information Baseline group similarity: Demos appear similar; higher AST and ALT in Silipide^®^ group | N: 65 Mean age: 48 Percent male: 71 Setting: Specialty clinic | Significant: AST, ALT Not significant: Bilirubin, albumin, PT

a Results not necessarily reported for all.

Abbreviations used: alk phos = alkaline phosphatase; ALT = alanine aminotranferase; AST = aspartase aminotranferase; CAH = chronic active hepatitis; CPH = chronic persistent hepatitis; demos = demographic variables; GGTP = gammaglutamyl transpeptidase; HCV = hepatitis C virus; LFT = liver function test; MVI = multivitamin; PT = prothrombin time; RCT = randomized controlled trial.

Summary Table 3. Placebo-controlled studies of milk thistle for acute viral hepatitis

Summary Table 3. Placebo-controlled studies of milk thistle for acute viral hepatitis

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Magliulo ^78^ Year: 1978 Country: Italy Language: German | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^)/420 mg daily/25 days Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, bilirubin, PT Followup interval: 1, 3, 5, 7, 9, 14, 21, 28 days Assessment time points with results reported: All followup | Type: Viral HAV and HBV Include: Acute HAV and HBV patients Exclude: Not given Acuity/severity: Acute, no other information Baseline group similarity: LFTs appear similar | N: 59 Mean age: 37 Percent male: 22 Setting: Hospital | Significant: AST, bilirubin + Trend: ALT Not significant: Alk phos Note: Trend was assessed qualitatively only for this review.

a Results not necessarily reported for all.

Abbreviations used: alk phos = alkaline phosphatase; ALT = alanine aminotranferase; AST = aspartase aminotranferase; GGTP = gammaglutamyl transpeptidase; HAV = hepatitis A virus; HBV = hepatitis B virus; LFT = liver function test; PT = prothrombin time; RCT = randomized controlled trial.

Summary Table 4. Placebo-controlled studies of milk thistle for chronic viral hepatitis

Summary Table 4. Placebo-controlled studies of milk thistle for chronic viral hepatitis

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Buzelli ^79^ Year: 1993 Country: Italy Language: English | Study type: RCT/blind Intervention/dose/duration: Silipide^®^ Control: Placebo Outcome measures^a^: AST, ALT, GGTP, MDA, alk phos, bilirubin, albumin Followup interval: 7 days Assessment time points with results reported: 7 days | Type: Chronic active hepatitis due to HBV and/or HCV Include: Biopsy-proven CAH, AST, and/or ALT greater than twice normal limits for more than 12 months; age 30 to 70 years old Exclude: Portal hypertension; hepatic encephalopathy, ascites, hepatocellular cancer, pruritus, icterus bilirubin, and alk phos more than twofold reference values; drug addiction and ANA, AMA, and ASMA; alcohol exceeding 30 g/d; malabsorption syndromes; cardiovascular, renal, or endocrine disorders; pregnancy; any drug treatment 3 months before beginning trial Acuity/severity: Chronic, AST or ALT greater than twice normal limits Baseline group similarity: Demos, LFTs appear similar | N: 20 Mean age: 53 Percent male: 30 Setting: Hospital | Significant: AST, ALT, GGTP Not significant: Bilirubin, alk phos, MDA, albumin
Author: Kiesewetter ^80^ Year: 1977 Country: Austria Language: German | Study type: RCT/quasi Intervention/dose/duration: Silymarin (Legalon^®^ )/420 mg daily/365 days Control: Placebo Outcome measures^a^: Histology Followup interval: 14, 30, 60 days then every 90 days to 1 year Assessment time points with results reported: One, combined/90 to 360 days | Type: Viral hepatitis (CPH and CAH) Include: CPH or CAH for more than 6 months; other medications for liver discontinued for 2 weeks or more Exclude: Disease less than 6 months; previous treatment with silymarin, steroids, or other cytotoxic drugs; alcohol exceeding 80 g/d or exceeding alcohol intake by laboratory values than patients' statement; other comorbidities requiring medications Acuity/severity: Chronic, no other information Baseline group similarity: Demos, similar, no information on LFTs | N: 24 Mean age: 53 Percent male: 50 Setting: Hospital | Significant: + Trend: Improvement in liver biopsy Not significant: Note: Trend was assessed qualitatively only for this review.

a Results not necessarily reported for all.

Abbreviations used: alk phos = alkaline phosphatase; ALT = alanine aminotranferase; AMA = antimitochondrial antibody; ANA = antinuclear antibody; ASMA = antismooth muscle antibody; AST = aspartase aminotranferase; CAH = chronic active hepatitis; CPH = chronic persistent hepatitis; demos = demographic variables; GGTP = gammaglutamyl transpeptidase; HBV = hepatitis B virus; HCV = hepatitis C virus; LFT = liver function test; MDA = malondialdehyde; RCT = randomized controlled trial.

Summary Table 5. Placebo-controlled studies of milk thistle and cirrhosis due to alcohol or other etiologies

Summary Table 5. Placebo-controlled studies of milk thistle and cirrhosis due to alcohol or other etiologies

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Benda ^76^ Year: 1980 Country: Germany Language: German | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^)/420 mg daily/ Unclear Control: Placebo MVI Outcome measures^a^: Survival Followup interval: 4 years Assessment time points with results reported: 4 years | Type: Alcoholic and nonalcoholic cirrhosis Include: Biopsy-proven cirrhosis Exclude: Moribund; poor compliance; immunosuppressive treatment in the past year; Prednisone in past 6 months; D-Penicillamine in past 3 months; primary biliary cirrhosis; Wilson's disease Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: No information | N: 172 Mean age: Not given Percent male: Not given Setting: Unclear | Significant: + Trend: Survival Not significant: Note: Trend was assessed qualitatively only for this review.
Author: Ferenci ^75^ Year: 1989 Country: Austria Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^)/420 mg daily/ mean 41 months, range 2 to 6 years Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, bilirubin, albumin, PT Followup interval: 4 years Assessment time points with results reported: 2 and 4 to 5.5 years for survival | Type: Alcoholic and nonalcoholic cirrhosis; cirrhosis with alcoholic hepatitis Include: Diagnosis of cirrhosis within 2 years before entering study Exclude: End-stage liver disease; known malignancies; primary biliary cirrhosis; immunosuppressive therapy Acuity/severity: Chronic, cirrhosis, Child's score A/B/C 89/69/12 Baseline group similarity: Demos, LFTs appear similar | N: 170 Mean age: 57 Percent male: 72 Setting: Primary care/community clinic, specialty clinic, hospital | Significant: Survival (alcohol disease, Child's score A) Not significant: (No data given; reported only as not significant) AST, ALT, GGTP, bilirubin, survival (nonalcohol disease, Child's score B and C) Correspondence from Ferenci, Oct. 10, 1999: Length of treatment was variable. All patients were treated for 2 years (original primary endpoint) and were continued on the same therapy until the last patient that entered completed 2 years of therapy. Mortality was 27/83 in placebo group and 20/83 in silymarin group.

a Results not necessarily reported for all.

Abbreviations used: alk phos = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartase aminotransferase; demos = demographic variables; GGTP = gammaglutamyl transpeptidase; LFT = liver function test; MVI = multivitamin; PT = prothrombin time; RCT = randomized controlled trial.

Summary Table 6. Placebo-controlled studies of milk thistle and alcoholic cirrhosis (other etiologies of cirrhosis excluded)

Summary Table 6. Placebo-controlled studies of milk thistle and alcoholic cirrhosis (other etiologies of cirrhosis excluded)

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Pares ^68^ Year: 1998 Country: Spain Language: English | Study type: RCT/blind Intervention/dose/duration: Silymarin (Legalon^®^)/450 mg daily/unclear Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, bilirubin, albumin, PT Followup interval: Every 3 months for 2 years Assessment time points with results reported: Survival at 5 years; all others at 2 years (assumed) | Type: Alcoholic cirrhosis (24 percent had superimposed alcohol hepatitis) Include: Chronic alcoholism defined as alcohol exceeding 80 g/d men and 60 g/d women for more than 5 years; biopsy or laparoscopic proven alcoholic cirrhosis Exclude: If ever received colchicine, malotilate, penicillamine, or corticosteroids; life expectancy less than 6 months; drug addicted or pregnant; other known etiologies for cirrhosis (i.e., HBV, autoimmunity, primary biliary cirrhosis, or cryptogenic cirrhosis) Acuity/severity: Chronic, all cirrhosis, Child's score A/B/C/ 63/114/14 Baseline group similarity: Demos, LFTs appear similar | N: 200 Mean age: 50 Percent male: 79 Setting: Diagnosis in hospital then outpatient followup. | Significant: + Trend: Encephalopathy, UGIB, survival for HCV-positive patients Not significant: AST, ALT, GGTP, PT, bilirubin, alk phos, hepatomegaly, splenomegaly, jaundice, ascites, survival Note: Trend was assessed qualitatively only for this review.
Author: Lang ^71^ Year: 1990 Country: Hungary Language: English | Study type: RCT/blind/three arms Interventions/dose/duration: Silymarin (Legalon^®^)/420 mg daily/30 days AICA-P/600 mg daily/30 days Control: Placebo Outcome measures^a^: AST, ALT, GGTP, alk phos, albumin Followup interval: 28 days Assessment time points with results reported: Weekly for 1 month | Type: Alcoholic cirrhosis Include: Alcohol intake exceeding 60 g/d in men and 30 g/d women for more than 6 years; histologic diagnosis of micronodular cirrhosis Exclude: Vascular and/or parenchymal decompensation; +HBsAg Acuity/severity: Chronic, cirrhosis, no other information Baseline group similarity: LFTs appear similar | N: 60 Mean age: 45 Percent male: 68 Setting: Unclear | Significant: AST, ALT, GGTP Not significant: Bilirubin

a Results not necessarily reported for all.

Abbreviations used: AICA-P = amino imidazol carboxamial phosphate; alk phos = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartase aminotransferase; demos = demographic variables; GGTP = gammaglutamyl transpeptidase; HBV = hepatitis B virus; HCV = hepatitis C virus; LFT = liver function test; PT = prothrombin time; RCT = randomized controlled trial; UGIB = upper gastrointestinal bleed.

Summary Table 7. Placebo-controlled study of milk thistle and toxin-induced liver disease

Summary Table 7. Placebo-controlled study of milk thistle and toxin-induced liver disease

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Palasciano ^81^ Year: 1994 Country: Italy Language: English | Study type: RCT/blind, factorial design Intervention/dose/duration: Silymarin and psychotropic drugs/800 mg silymarin daily/ 90 days Silymarin and psychotropic drugs discontinued/800 mg daily/90 days Control: Placebo and no psychotropic drugs discontinued Placebo and psychotropic drugs/ not given/90 days Outcome measures^a^: AST, ALT, MDA Followup interval: Day 15, 30, 60, 90, 120 Assessment time points with results reported: 30, 60, 90, and 120 days for MDA; 30 and 90 for AST and ALT | Type: Drug-induced liver disease (some patients were HBV-positive) Include: Women 40 to 60 years old; hospitalized; phenothiazines and/or butyrophenones for 5 years; AST or ALT greater than twice normal limits Exclude: Current therapy with other drugs that could influence progress of hepatopathy; other hepatopathies (alcohol, viral, autoimmune, hemochromatosis, Wilson's disease, porphyria cutanea tarda, primary or secondary hepatic neoplasia); BUN exceeding 60 mg/dL and/or creatinine exceeding 2.5 mg/dL; cardiac and circulatory insufficiency; diabetes mellitus; other important extrahepatic diseases; verified or presumed pregnancy; alcohol (more than 30 g/d) or opiate abuse Acuity/severity: Chronic; AST or ALT greater than two times the normal limit Baseline group similarity: Demos similar; LFTs variable | N: 60 Mean age: 52 Percent male: 0 Setting: Hospital | Significant: MDA for psychotropic drugs with silymarin versus placebo Not significant: AST, ALT, MDA for psychotropic drugs discontinued, silymarin versus placebo

a Results not necessarily reported for all.

Abbreviations used: ALT = alanine aminotranferase; AST = aspartase aminotranferase; BUN = blood urea nitrogen; demos = demographic variables; HBV = hepatitis B virus; LFT = liver function test; MDA = malondialdehyde; RCT = randomized controlled trial.

Summary Table 8. Prophylactic milk thistle with hepatotoxic drugs

Summary Table 8. Prophylactic milk thistle with hepatotoxic drugs

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Magula ^82^ Year: 1996 Country: Language: Slovak | Study type: RCT/not blinded/prophylaxis Intervention/dose/duration tuberculosis treatment and Hepabene^®^ (Silymarin and Fumaria officinalis alkaloids)/2 capsules daily/ 8 weeks Control: Tuberculosis medications alone Outcome measures^a^: AST, ALT, bilirubin, "liver injury," interruption of tuberculosis medications Followup interval: Every 2 weeks for 8 weeks Assessment time points with results reported: 8 weeks (56 days) | Type: Drug-induced liver disease Include: Patients requiring tuberculosis treatment; normal LFTs at baseline Exclude: Not given Acuity/severity: No disease at baseline | N: 172 (92 tuberculosis medications alone; 29 tuberculosis medications plus silymarin) Mean age: 50 Percent male: 60 Setting: Unclear | Significant: AST, ALT Not significant:
Author: Allain ^83^ Year: 1999 Country: France Language: English | Study type: RCT/blind/prophylaxis Intervention/dose/duration: Silymarin/420 mg daily/84 days Control: Placebo Outcome measures^a^: AST, ALT Followup interval: 8 times over 15 weeks Assessment time points with results reported: 8 times over 15 weeks | Type: Drug- (Tacrine-) induced liver disease Include: Patient over 50 years old; mild to moderate Alzheimer's disease; Tacrine treatment Exclude: Past history hepatic disorder (cirrhosis, increased bilirubin, AST, and/or ALT) Acuity/severity: No disease at baseline | N: 222 Mean age: Approximately 74 Percent male: 39 Setting: Specialty clinic | Significant: Not significant: AST, ALT

a Results not necessarily reported for all.

Abbreviations used: ALT = alanine aminotransferase; AST = aspartase aminotransferase; LFT = liver function test; RCT = randomized controlled trial.

Summary Table 9. Phase II study of Silipide®

Summary Table 9. Phase II study of Silipide®

Study | Design | Liver Disease | Subject Characteristics | Outcomes (favoring silymarin unless otherwise noted)
Author: Vailati^85^ Year: 1993 Country: Italy Language: English | Study type: RCT/not blind/Phase II study Intervention/dose/duration: Silymarin (Silipide^®^)/160 mg silybin equivalents daily/14 days Silymarin (Silipide^®^)/240 mg silybin equivalents daily/14 days Silymarin (Silipide^®^ )/360 mg silybin equivalents daily/14 days Control: No treatment Outcome measures^a^: AST, GGTP, bilirubin Followup interval: 7, 14 days Assessment time points with results reported: 7, 14 days | Type: Viral and alcoholic hepatitis Include: Biopsy-proven chronic hepatitis (viral or alcoholic); AST and ALT 1.5 or greater than 2 times normal limits and biopsy within 1 year Exclude: Other forms of liver disease; decompensated liver disease; treatment with interferon, antivirals, immunosuppressants, or immunodulators for 6 months or less Acuity/severity: Chronic, no other information | N: 60 Mean age: 50 Percent male: 62 Setting: Outpatient clinic | Significant: AST, GGTP, bilirubin for 240 or 360 mg versus 160 mg Not significant:

a Results not necessarily reported for all.

Abbreviations used: ALT = alanine aminotransferase; AST = aspartase aminotransferase; GGTP = gammaglutamyl transpeptidase; RCT = randomized controlled trial.

Summary Table 10. Effect sizes and meta-analyses of 16 placebo-controlled trials (Evidence Tables 1 and 2)

Summary Table 10. Effect sizes and meta-analyses of 16 placebo-controlled trials (Evidence Tables 1 and 2)

Outcome ^a^ | Time of Followup | No. of Studies | Effect Size (SD units) 95% CI | Effect Size, Clinical Units ^b^ 95% CI | p Value ^c^ (ES ≠ 0) | Q p Value ^c^ (homogeneity)
AST without drug study 44.77 U/L ^a^ | <45 days | 6 | -0.25 (-0.47 to -0.02) | -11.2 (-21.0 to -0.9) | 0.03 | 0.83
AST without drug study 44.77 U/L ^a^ | 90 days | 3 | -0.27 (-0.96 to 0.42) | -12.1 (-4.30 to 89.5) | 0.44 | 0.014
AST without drug study 44.77 U/L ^a^ | 90 days without outlier | 2 | -0.02 (-0.76 to 0.72) | -0.9 (-34.0 to 32.2) | 0.96 | 0.06
AST without drug study 44.77 U/L ^a^ | 180 days | 1 | -0.37 (-1.03 to 0.29) | -16.6 (-46.1 to 13.0) | 0.27 | --
AST without drug study 44.77 U/L ^a^ | 15 months | 1 | 0.37 (-0.21 to 0.95) | 17.5 (-9.4 to 42.5) | 0.21 | --
AST without drug study 44.77 U/L ^a^ | 2 years | 1 | 0.28 (-0.07 to 0.63) | 12.5 (-3.1 to 28.2) | 0.12 | --
AST with drug study 44.77 U/L ^a^ | <45 days | 8 | -0.21 (-0.42 to -0.004) | -9.4 (-18.8 to -0.2) | 0.046 | 0.90
AST with drug study 44.77 U/L ^a^ | 90 days | 5 | -0.30 (-0.73 to 0.13) | -13.4 (-32.7 to 5.8) | 0.17 | 0.03
AST with drug study 44.77 U/L ^a^ | 90 days without outlier | 4 | -0.53 (-0.85 to -0.22) | -23.7 (-38.0 to -9.8) | 0.001 | 0.79
ALT without drug study 36.02 U/L ^a^ | <45 days | 7 | -0.09 (-0.45 to 0.28) | -3.2 (-16.2 to 10.1) | 0.64 | 0.004
ALT without drug study 36.02 U/L ^a^ | <45 days without outlier | 6 | -0.22 (-0.42 to -0.03) | -7.9 (-15.1 to -1.1) | 0.03 | 0.51
ALT without drug study 36.02 U/L ^a^ | 90 days | 2 | -0.65 (-1.15 to -0.15) | -23.4 (-41.4 to -5.4) | 0.01 | 0.28
ALT without drug study 36.02 U/L ^a^ | 180 days | 1 | -0.28 (-0.94 to 0.38) | -10.1 (-33.9 to 13.7) | 0.41 | --
ALT without drug study 36.02 U/L ^a^ | 2 years | 1 | 0.33 (-0.02 to 0.68) | 11.9 (-0.7 to 24.5) | 0.07 | --
ALT with drug study 36.02 U/L ^a^ | <45 days | 9 | -0.07 (-0.37 to 0.23) | -2.5 (-13.3 to 8.3) | 0.66 | 0.01
ALT with drug study 36.02 U/L ^a^ | <45 days without outlier | 8 | -0.19 (-0.37 to -0.01) | -6.8 (-13.3 to -0.4) | 0.04 | 0.63
ALT with drug study 36.02 U/L ^a^ | 90 days | 4 | -0.48 (-0.83 to -0.14) | -17.3 (-29.9 to -5.0) | 0.01 | 0.53
GGTP 153.94 U/L ^a^ | <45 days | 5 | -0.21 (-0.45 to 0.02) | -32.3 (-69.3 to 3.1) | 0.08 | 0.35
GGTP 153.94 U/L ^a^ | 90 days | 2 | -0.04 (-0.41 to 0.32) | -6.2 (-63.1 to 49.3) | 0.81 | 0.93
GGTP 153.94 U/L ^a^ | 180 days | 1 | -0.64 (-1.30 to 0.02) | -98.5 (-200.1 to 3.1) | 0.06 | --
GGTP 153.94 U/L ^a^ | 15 months | 1 | -0.26 (-0.84 to 0.32) | -40.0 (-129.3 to 49.3) | 0.38 | --
GGTP 153.94 U/L ^a^ | 2 years | 1 | 0.38 (0.02 to 0.73) | 58.5 (3.1 to 112.4) | 0.04 | --
MDA 6.65 nmol/ml ^a^ | <45 days | 1 | -0.09 (-0.96 to 0.79) | -0.6 (-6.4 to 5.3) | 0.85 | --
MDA 6.65 nmol/ml ^a^ | 180 days | 1 | -0.81 (-1.49 to -1.13) | -5.3 (-9.9 to -7.5) | 0.02 | --
Alkaline phosphate 101.01 U/L ^a^ | <45 days | 5 | -0.04 (-0.25 to 0.16) | -4.0 (-25.3 to 16.2) | 0.68 | 0.61
Alkaline phosphate 101.01 U/L ^a^ | 90 days | 1 | 0.10 (-0.55 to 0.76) | 10.1 ( 55.6 to 76.8) | 0.76 | --
Alkaline phosphate 101.01 U/L ^a^ | 180 days | 1 | -0.34 (-1.00 to 0.34) | -34.3 (-101.0 to 34.3) | 0.31 | --
Alkaline phosphate 101.01 U/L ^a^ | 15 months | 1 | -0.05 (-0.63 to 0.53) | -5.0 (-63.6 to 53.5) | 0.87 | --
Alkaline phosphate 101.01 U/L ^a^ | 2 years | 1 | -0.08 (-0.43 to 0.27) | -8.1 (-43.4 to 27.3) | 0.66 | --
Bilirubin 0.32 g/dL ^a^ | <45 days | 4 | -0.28 (-0.52 to -0.03) | -0.1 (-0.2 to -0.01) | 0.03 | 1.00
Bilirubin 0.32 g/dL ^a^ | 90 days | 3 | 0.02 (-0.33 to 0.37) | 0.01(-0.1 to 0.1) | 0.91 | 0.25
Bilirubin 0.32 g/dL ^a^ | 180 days | 1 | -0.49 (-1.15 to 0.17) | -0.2 (-0.4 to 0.05) | 0.15 | --
Bilirubin 0.32 g/dL ^a^ | 15 months | 1 | -0.16 (-0.74 to 0.43) | -0.05 (-0.2 to 0.1 | 0.60 | --
Bilirubin 0.32 g/dL ^a^ | 2 years | 1 | 0.00 (-0.35 to 0.36) | 0.0 (-0.1 to 0.1) | 1.00 | --
Albumin 0.74 g/dL ^a^ | 90 days | 3 | -0.08 (-0.53 to 0.38) | -0.05 (-0.4 to 0.3) | 0.74 | 0.10
Albumin 0.74 g/dL ^a^ | 180 days | 1 | 0.19 (-0.46 to 0.84) | 0.1 (-0.3 to 0.6) | 0.57 | --
Albumin 0.74 g/dL ^a^ | 15 months | 1 | 0.25 (-0.35 to 0.85) | 0.2 (-0.2 to 0.6) | 0.42 | --
Albumin 0.74 g/dL ^a^ | 2 years | 1 | -0.23 (-0.58 to 0.12) | -0.2 (-0.4 to 0.1) | 0.20 | --
PT 17.39 ^a^ seconds | <45 days | 1 | 0.14 (-0.16 to 0.44) | 2.4 (-2.8 to 7.7) | 0.35 | --
PT 17.39 ^a^ seconds | 90 days | 3 | -0.19 (-0.67 to 0.28) | -3.3 (-11.6 to 4.9) | 0.42 | 0.08
PT 17.39 ^a^ seconds | 180 days | 1 | 0.47 (-0.20 to 1.14) | 8.2 (-3.5 to 19.8) | 0.17 | --
PT 17.39 ^a^ seconds | 15 months | 1 | -0.29 (-0.87 to 0.29) | -5.0 (-15.1 to 5.0) | 0.32 | --
PT 17.39 ^a^ seconds | 2 years | 1 | -0.18 (-0.53 to 0.17) | -3.1 (-9.2 to 3.0) | 0.31 | --
Child's 2.55 score | 15 months | 1 | -0.09 (-0.68 to 0.50) | -0.2 (-1.7 to 1.3) | 0.78 | --
Child's 2.55 score | 2 years | 1 | 0.27 (-0.08 to 0.62) | 0.7 (-0.2 to 1.6) | 0.13 | --

When there was more than one study, effect sizes were pooled.

a Mean pooled standard deviations.

b Standard deviation effect size units are back-converted to clinical effect sizes by standard deviation x effect size.

c All studies refer to combination of chronic alcohol, chronic and acute viral, and chronic mixed etiology unless otherwise noted (the inclusion of one drug study, factorial design); values reported for meta-analytic results; N/A for single study estimates.

Abbreviations used: ALT = alanine aminotranferase; AST = aspartase aminotranferase; CI = 95% confidence interval; ES = effect size; GGTP = gammaglutamyl transpeptidase; MDA = malondialdehyde; PT = prothrombin time; SD = standard deviation; U/L = units per liter.

Summary Table 11. Effect sizes and meta-analyses of 14 randomized, placebo-controlled trials of higher methodological quality (Evidence Table 1)

Summary Table 11. Effect sizes and meta-analyses of 14 randomized, placebo-controlled trials of higher methodological quality (Evidence Table 1)

Outcome ^a^ | Time of Followup | No. of Studies | Effect Size (SD units) 95% CI | Effect Size, Clinical Units ^b^ 95% CI | p Value ^c^ (E ≠ 0) | Q p Value ^c^ (Homogeneity)
AST without drug study 44.77 U/L ^a^ | <45 days | 5 | -0.27 (-0.52 to -0.03) | -12.1 (-23.3 to -1.3) | 0.03 | 0.76
AST without drug study 44.77 U/L ^a^ | 90 days | 2 | -0.02 (-0.76 to 0.72) | -0.9 (-34.0 to 32.2) | 0.96 | 0.06
AST without drug study 44.77 U/L ^a^ | 180 days | 1 | -0.37 (-1.03 to 0.29) | -16.6 (-46.1 to 13.0) | 0.27 | --
AST without drug study 44.77 U/L ^a^ | 15 months | 1 | 0.37 (-0.21 to 0.95) | 17.5 (-9.4 to 42.5) | 0.21 | --
AST without drug study 44.77 U/L ^a^ | 2 years | 1 | 0.28 (-0.07 to 0.63) | 12.5 (-3.1 to 28.2) | 0.12 | --
AST with drug study 44.77 U/L ^a^ | <45 days | 7 | -0.23 (-0.46 to -0.004) | -10.3 (-20.6 to -0.2) | 0.046 | 0.85
AST with drug study 44.77 U/L ^a^ | 90 days | 4 | -0.15(-0.58 to 0.27) | -1.8 (-18.4 to 14.8) | 0.48 | 0.14
ALT without drug study 36.02 U/L ^a^ | <45 days | 6 | -0.14 (-0.55 to 0.28) | -5.0 (-19.8 to 10.1) | 0.52 | 0.003
ALT without drug study 36.02 U/L ^a^ | <45 days without outlier | 5 | -0.27 (-0.48 to -0.07) | -9.7 (-17.3 to -2.5) | 0.01 | 0.71
ALT without drug study 36.02 U/L ^a^ | 90 days | 1 | -0.39 (-1.05 to 0.27) | -14.0 (-37.8 to 9.7) | 0.24 | --
ALT without drug study 36.02 U/L ^a^ | 180 days | 1 | -0.28 (-0.94 to 0.38) | -10.1 (-33.9 to 13.7) | 0.41 | --
ALT without drug study 36.02 U/L ^a^ | 2 years | 1 | 0.33 (-0.02 to 0.68) | 11.9 (-0.7 to 24.5) | 0.07 | --
ALT with drug study 36.02 U/L ^a^ | <45 days | 8 | -0.10 (-0.43 to 0.23) | -3.6 (-15.5 to 8.3) | 0.54 | 0.01
ALT with drug study 36.02 U/L ^a^ | <45 days without outlier | 7 | -0.23 (-0.42 to -0.04) | -8.3 (-15.1 to -1.4) | 0.02 | 0.76
ALT with drug study 36.02 U/L ^a^ | 90 days | 3 | -0.33 (-0.73 to 0.08) | -11.9 (-26.3 to 2.9) | 0.11 | 0.96
GGTP 153.94 U/L ^a^ | <45 days | 5 | -0.21 (-0.45 to 0.02) | -32.3 (-69.3 to 3.1) | 0.08 | 0.35
GGTP 153.94 U/L ^a^ | 90 days | 2 | -0.04 (-0.41 to 0.32) | -6.2 (-63.1 to 49.3) | 0.81 | 0.93
GGTP 153.94 U/L ^a^ | 180 days | 1 | -0.64 (-1.30 to 0.02) | -98.5 (-200.1 to 3.1) | 0.06 | --
GGTP 153.94 U/L ^a^ | 15 months | 1 | -0.26 (-0.84 to 0.32) | -40.0 (-129.3 to 49.3) | 0.38 | --
GGTP 153.94 U/L ^a^ | 2 years | 1 | 0.38 (0.02 to 0.73) | 58.5 (3.1 to 112.4) | 0.04 | --
MDA 6.65 nmol/ml ^a^ | <45 days | 1 | -0.09 (-0.96 to 0.79) | -0.6 (-6.4 to 5.3) | 0.85 | --
MDA 6.65 nmol/ml ^a^ | 180 days | 1 | -0.81 (-01.49 to -1.13) | -5.4 (-9.9 to -7.5) | 0.02 | --
Alkaline Phosphate 101.01 U/L ^a^ | <45 days | 4 | -0.04 (-0.26 to 0.17) | -4.0 (-26.3 to 17.2) | 0.70 | 0.44
Alkaline Phosphate 101.01 U/L ^a^ | 90 days | 1 | 0.10 (-0.55 to 0.76) | 10.1 (-55.6 to 76.8) | 0.76 | --
Alkaline Phosphate 101.01 U/L ^a^ | 180 days | 1 | -0.34 (-1.00 to 0.34) | -34.3 (-101.0 to 34.3) | 0.31 | --
Alkaline Phosphate 101.01 U/L ^a^ | 15 months | 1 | -0.05 (-0.63 to 0.53) | -5.0 (-63.6 to 53.5) | 0.87 | --
Alkaline Phosphate 101.01 U/L ^a^ | 2 years | 1 | -0.08 (-0.43 to 0.27) | -8.1 (-43.4 to 27.3) | 0.66 | --
Bilirubin 0.32 g/dL ^a^ | <45 days | 4 | -0.28 (-0.52 to -0.03) | -0.1 (-0.2 to -0.01) | 0.03 | 1.0
Bilirubin 0.32 g/dL ^a^ | 90 days | 2 | -0.10 (-0.70 to 0.49) | -0.03 (-0.2 to 0.2) | 0.73 | 0.13
Bilirubin 0.32 g/dL ^a^ | 180 days | 1 | -0.49 (-1.15 to 0.17) | -0.2 (-0.4 to 0.05) | 0.15 | --
Bilirubin 0.32 g/dL ^a^ | 15 months | 1 | -0.16 (-0.74 to 0.43) | -0.05 (-0.2 to 0.1) | 0.60 | --
Bilirubin 0.32 g/dL ^a^ | 2 years | 1 | 0.00 (-0.35 to 0.36) | 0.0 (-0.1 to 0.1) | 1.00 | --
Albumin 0.74 g/dL ^a^ | 90 days | 2 | -0.13 (-0.87 to 0.60) | -0.1(-0.6 to 0.4) | 0.72 | 0.06
Albumin 0.74 g/dL ^a^ | 180 days | 1 | 0.19 (-0.46 to 0.84) | 0.1 (-0.3 to 0.6) | 0.57 | --
Albumin 0.74 g/dL ^a^ | 15 months | 1 | 0.25 (-0.35 to 0.85) | 0.2 (-0.2 to 0.6) | 0.42 | --
Albumin 0.74 g/dL ^a^ | 2 years | 1 | -0.23 (-0.58 to 0.12) | -0.2 (-0.4 to 0.1) | 0.20 | --
PT 17.39 ^a^ seconds | <45 days | 1 | 0.14 (-0.16 to 0.44) | 2.4 (-2.8 to 7.7) | 0.35 | --
PT 17.39 ^a^ seconds | 90 days | 2 | -0.30 (-1.00 to 0.40) | -5.2 (-17.4 to 7.0) | 0.40 | 0.08
PT 17.39 ^a^ seconds | 180 days | 1 | 0.47 (-0.20 to 1.14) | 8.2 (-3.5 to 19.8) | 0.17 | --
PT 17.39 ^a^ seconds | 15 months | 1 | -0.29 (-0.87 to 0.29) | -5.0 (-15.1 to 5.0) | 0.32 | --
PT 17.39 ^a^ seconds | 2 years | 1 | -0.18 (-0.53 to 0.17) | -3.1(-9.2 to 3.0) | 0.31 | --
Child's 2.55 score | 15 months | 1 | -0.09 (-0.68 to 0.50) | -0.2 (-1.7 to 1.3) | 0.76 | --
Child's 2.55 score | 2 years | 1 | 0.27 (-0.08 to 0.62) | 0.7 (-0.2 to 1.6) | 0.13 | --

When there was more than one study, effect sizes were pooled.

a Mean pooled standard deviations.

b Standard deviation effect size units are back-converted to clinical effect sizes by standard deviation x effect size.

c All studies refer to combination of chronic alcohol, chronic and acute viral, and chronic mixed etiology unless otherwise noted (the inclusion of one drug study, factorial design); values reported for meta-analytic results; N/A for single study estimates.

Abbreviations used: ALT = alanine aminotranferase; AST = aspartase aminotranferase; CI = 95% confidence interval; ES = effect size; GGTP = gammaglutamyl transpeptidase; MDA = malondialdehyde; PT = prothrombin time; SD = standard deviation; U/L = units per liter.

Summary Table 12. Adverse effects of oral use of milk thistle, silymarin, or Silipide®

Summary Table 12. Adverse effects of oral use of milk thistle, silymarin, or Silipide®

Adverse Effects | Level of Evidence
Possible/probable anaphylaxis | Three case reports
Gastrointestinal Nausea, diarrhea, upset stomach, epigastric discomfort, heartburn, dyspepsia, flatulence, meteorism, "uneasiness" of stomach, vomiting, anorexia, change in bowel movement, "gastric intolerance," abdominal fullness or pain | Four RCTs: silymarin < control Five cohort studies: 0.3% 2%, 5%, 6%, 8% 11 occurrences/975 patients 9 occurrences/2,169 patients
Headache | Three RCTs: < control Two cohort studies: 0.04%, 0.04%
Skin: Itching, pruritus Exanthem, urticaria, skin rash, eczema | Two RCTs: silymarin < control Three cohort studies: 2 occurrences/2,637 patients 2 occurrences/975 patients 2 occurrences/2,169 patients Two RCTs: silymarin < control Two cohort studies: 2 occurrences/975 patients 1 occurrence/2,169 patients
Other: Decreased energy, discomfort, indisposition, decreased energy, restlessness Asthenia, malaise, irritability Insomnia Arthalgia Rhinoconjunctivitis Impotence | Cohort study: 0.3% 1 occurrence/975 patients 1 occurrence/2,169 patients One RCT: silymarin < control One RCT: silymarin < control One RCT: silymarin < control One case report One RCT: 1/29 silymarin, 0/31 control

Frequency of adverse effects was sometimes reported as the following: (1) percent of subjects, (2) number of subjects, or (3) number of occurrences of adverse effects in a group of subjects without detail about subjects who may have had more than one adverse effect.

RCT = randomized controlled trial.