# References

Brown D. Silymarin education monograph. Herbal Res Update. 1993;Summer:23-36.
Foster S. Milk thistle: Silybum marianum. Austin (TX): American Botanical Council; 1990.
Luper S. A review of plants used in the treatment of liver disease: Part 1. Altern Med Rev. 1998;3:410-21. [pmid: 9855566].
Tenney L. Milk thistle: A remarkable flavonoid antioxidant and liver protectant. Pleasant Grove (UT): Woodlands Publications; 1995.
Morazzoni P, Bombardelli E. Silybum marianum (Carduus marianus). Fitoterapia. 1995;66:3-42.
Herbal remedies. Milk thistle: Protection for the liver [Web site]. Available at: http://www.healthyideas.com/healing/herb/980407.herb.html. [accessed June 25, 1999].
Hobbs C. Milk thistle: The liver herb. Loveland (CO): Interweave Press; 1994.
Grieve M. A modern herbal: The medicinal, culinary, cosmetic and economic properties, cultivation, and folklore of herbs, grasses, fungi, shrubs, and trees with all their modern scientific uses. Darien (CT): Hafner Publishing Company; 1931.
Flora K, Hahn M, Rosen H, et al. Milk thistle (Silybum marianum) for the therapy of liver disease. Am J Gastroenterol. 1998;93:139-43. [pmid: 9468229].
Bergner P. Botanical medicine: Silybum marianum and liver therapy. Townsend Lett Doctors. 1988;61-2:348-9.
Folk medicine traditions [Web site]. Available at: http://nccam.nih.gov/nccam/ what-is-cam/fields/herbals.shtml. [accessed June 28, 1999].
Blumenthal M, editor. Complete German Commission E monographs: Therapeutic guide to herbal medicines. Boston (MA): American Botanical Council, Integrative Medicine Communications; 1998.
Flora KD, Rosen HR, Benner KG. The use of naturopathic remedies for chronic liver disease. Am J Gastroenterol. 1996;91:2654-5. [pmid: 8947022].
Gottlieb S. US agency to test safety of four herbs [newsletter]. BMJ. 1999;319. [pmcid: 28276].
Miller AL. Antioxidant flavonoids: Structure, function and clinical usage. Altern Med Rev. 1996;1:103-11.
Valenzuela A, Garrido A. Biochemical bases of the pharmacological action of the flavonoid silymarin and of its structural isomer silibinin. Biol Res. 1994;27:105-12. [pmid: 8640239].
Schulz V, Hansel R, Tyler VE, editors. Rational phytotherapy: A physician's guide to herbal medicine. 3rd, fully rev., and expanded ed. Berlin: Springer-Verlag; 1998.
Mascher H, Kikuta C, Weyhenmeyer R. Diastereomeric separation of free and conjugated silibinin in plasma by reversed phase HPLC after specific extraction. J Liquid Chromatogr. 1993;16:2777-89.
Blumenthal M (National Advisory Panel Member). Personal communication from Mark Blumenthal, Dec 1999.
Ely H. Dermatologic therapies you've probably never heard of. Dermatol Clin. 1989;7:19-35. [pmid: 2646047].
Blumenthal M (National Advisory Panel Member). Personal communication from Mark Blumenthal, Dec 1999.
Blumenthal M (National Advisory Panel Member). Conference telephone call with the San Antonio Evidence-based Practice Center, Oct 19, 1999.
Blumenthal M (National Advisory Panel Member). Personal communication from Mark Blumenthal, Dec 1999, who cited: (A) personal communication from Madaus through E. Leng-Peschlow and A. Strenge-Hesse, Nov 1999; (B) Schulz HU, et al. Untersuchungen zum Freisetzungsverhalten und zur Bioäquivalenenz von Silymarin-Präparaten. Arzneimittelforshung 1995;45: 61-4; (C) Frömming KH, et al. Silymarinhaltige Phytopharmaka: Biopharmazie als wesentliches therapeutisches Qualitätskriterium. Z Ärztl Fortbild Qual. 1999;4:vi-xi.
Pifferi G. A new bioavailable complex of Silybin: Part I. Pharmacol Res. 1993;27:123-4.
Barzaghi N, Crema F, Gatti G, et al. Pharmacokinetic studies on IdB 1016, a silybin-phosphatidylcholine complex, in healthy human subjects. Eur J Drug Metab Pharmacokinet. 1990;15:333-8. [pmid: 2088770].
Schandalik R, Gatti G, Perucca E. Pharmacokinetics of silybin in bile following administration of silipide and silymarin in cholecystectomy patients. Arzneimittelforschung. 1992;42:964-8. [pmid: 1329780].
Orlando R, Fragasso A, Lampertico M, et al. Silybin kinetics in patients with liver cirrhosis: A comparative study of silybin-phosphatidilcholine complex and silymarin. Med Sci Res. 1990;18:861-3.
Pifferi G, Magistretti MJ. A new bioavailable complex of silybin: Part II. Pharmacol Res. 1993;27:125-6.
Rajasekaran A, Kumar M, Krishnamoorthy G, et al. Spectrophotometric determination of silymarin. Indian J Pharm Sci. 1997;59:230-1.
Gocan S, Cimpan G, Muresan L. Automated multiple development thin layer chromatography of some plant extracts. J Pharm Biomed Anal. 1996;14:1221-7. [pmid: 8818037].
Weyhenmeyer R, Mascher H, Birkmayer J. Study on dose-linearity of the pharmacokinetics of silibinin diastereomers using a new stereospecific assay. Int J Clin Pharmacol Ther Toxicol. 1992;30:134-8. [pmid: 1572758].
Hammouda F, Ismail S, Hassan N, et al. Evaluation of the silymarin content in Silybum marianum (L.) Gaertn. cultivated under different agricultural conditions. Phytother Res. 1993;7:90-1.
Tittel G, Wagner H. High-performance liquid chromatographic separation of silymarins and their determination in a raw extract of Silybum marianum Gaertn. J Chromatogr. 1977;135:499-501. [pmid: 874032].
Quaglia MG, Bossu E, Donati E, et al. Determination of silymarine in the extract from the dried silybum marianum fruits by high performance liquid chromatography and capillary electrophoresis. J Pharm Biomed Anal. 1999;19:435-42. [pmid: 10704109].
Bindoli A, Cavallini L, Siliprandi N. Inhibitory action of silymarin of lipid peroxide formation in rat liver mitochondria and microsomes. Biochem Pharmacol. 1977;26:2405-9. [pmid: 597328].
Valenzuela A, Guerra R, Videla LA. Antioxidant properties of the flavonoids silybin and (+)-cyanidanol-3: Comparison with butylated hydroxyanisole and butylated hydroxytoluene. Planta Med. 1986;6:438-40. [pmid: 3562659].
Valenzuela A, Guerra R. Differential effect of silybin on the Fe2+-ADP and t-butyl hydroperoxide-induced microsomal lipid peroxidation. Experientia. 1986;42:139-41. [pmid: 3948968].
Valenzuela A, Barria T, Guerra R, et al. Inhibitory effect of the flavonoid silymarin on the erythrocyte hemolysis induced by phenylhydrazine. Biochem Biophys Res Commun. 1985;126:712-8. [pmid: 3977887].
Mira ML, Azevedo MS, Manso C. The neutralization of hydroxyl radical by silibin, sorbinil and bendazac. Free Radic Res Commun. 1987;4:125-9. [pmid: 3508133].
Gyorgy I, Blazovics A, Feher J, et al. Reactions of inorganic free radicals with liver protecting drugs. Radiat Phys Chem. 1990;36:165-7.
Muzes G, Deak G, Lang I, et al. Effect of the bioflavonoid silymarin on the in vitro activity and expression of superoxide dismutase (SOD) enzyme. Acta Physiol Hung. 1991;78:3-9. [pmid: 1763650].
Campos R, Garrido A, Guerra R, et al. Silybin dihemisuccinate protects against glutathione depletion and lipid peroxidation induced by acetaminophen on rat liver. Planta Med. 1989;55:417-9. [pmid: 2813577].
Halliwell B, Gutteridge JM. The antioxidants of human extracellular fluids. [Review]. [129 refs]. Arch Biochem Biophys. 1990 Jul;280:1-8. [pmid: 2191627].
Feher JLI, Nekam K, Gergely P, et al. In vivo effect of free radical scavenger hepatoprotective agents on superoxide dismutase (SOD) activity in patients. Tokai J Exp Clin Med. 1990;15(2-3):129-34. [pmid: 2130521].
Hikino H, Kiso Y, Wagner H, et al. Antihepatotoxic actions of flavonolignans from Silybum marianum fruits. Planta Med. 1984;50:248-50. [pmid: 6091165].
Faulstich H, Jahn W, Wieland T. Silybin inhibition of amatoxin uptake in the perfused rat liver. Arzneimittelforschung. 1980;30:452-4. [pmid: 7387753].
Tuchweber B, Sieck R, Trost W. Prevention of silybin of phalloidin-induced acute hepatoxicity. Toxicol Appl Pharmacol. 1979;51:265-75. [pmid: 531892].
Sonnenbichler J, Zetl I. Biochemical effects of the flavoligand silybin on RNA, protein and DNA synthesis of macromolecules in liver cells. In: Cody V, Middleton E Jr, Harborne JB, editors. Plant flavanoids in biology and medicine: Biochemical, pharmacological, and structure-activity relationships. New York: Liss; 1986. p. 319-31.
Magliulo E, Carosi PG, Minoli L, et al. Studies on the regenerative capacity of the liver in rats subjected to partial hepatectomy and treated with silymarin. Arzneimittelforschung. 1973;23:161-7. [pmid: 4740690].
Sonnenbichler J, Goldberg M, Hane L, et al. Stimulatory effect of Silibinin on the DNA synthesis in partially hepatectomized rat livers: Non-response in hepatoma and other malign cell lines. Biochem Pharmacol. 1986;35:538-41. [pmid: 3004503].
Blumenthal M (National Advisory Panel Member). Personal communication from Mark Blumenthal, Dec 1999, who cited: (A) personal communication from Madaus through E. Leng-Peschlow and A. Strenge-Hesse, Nov 1999; (B) Schuppan D, et al. Antibrotic effect of silymarin in rat secondary bilary fibrosis induced by bile duct obliteration with ethibloc [abstract]. Z Gastroenterol 1994;32: 45-6; (C) Jia JD, et al. Silymarin decreases type I procollogen mRNA levels in rats with secondary biliary cirrhosis [abstract]. Gastroenterology 114;A1265; (D) Boigk G, et al. Silymarin retards collagen accumulation in early and advanced biliary fibrosis secondary to complete bile duct obliteration in rats. Hepatology. 1997;26:643-9. [pmid: 9303494].
Dehmlow C, Murawski N, de Groot H. Scavenging of reactive oxygen species and inhibition of arachidonic acid metabolism by silibinin in human cells. Life Sci. 1996;58:1591-600. [pmid: 8649189].
Dennehy C. Personal communication from Cathi Dennehy, Dec 1999.
Bode JC. Re: Flora, et al. Silymarin for the therapy of liver disease. Am J Gastroenterol. 1999;94:545-6. [pmid: 10022676].
Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350:185-6. [pmid: 9250191].
Naranjo CA, Busto U, Sellers EM, et al. A method for estimating the probability of adverse drug reactions. Clin Pharmacol Ther. 1981;30:239-45. [pmid: 7249508].
Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando (FL): Academic Press; 1985.
Rosenthal R. Meta-analytic procedures for social research. Rev. ed. Thousand Oaks (CA): Sage Publications; 1991.
Berkey CS, Hoaglin DC, Mosteller F, et al. A random-effects regression model for meta-analysis. Stat Med. 1995;14:395-411. [pmid: 7746979].
Sharp S. Sbe23: Meta-regression. Stata Tech Bull. 1998;42:16-22.
Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-34. [pmid: 9310563].
Tobias A. Assessing heterogeneity in meta-analysis: The Galbraith plot. Stata Tech Bull. 1997;41:15-7.
Sharp S, Sterne J. Sbe16: Meta-analysis. Stata Tech Bull. 1997;38:9-14.
Steichen TJ. Tests for publication bias in meta-analysis. Stata Tech Bull. 1997;41:9-15.
Flisiak R, Prokopowicz D. Effect of misoprostol on the course of viral hepatitis B. Hepatogastroenterology. 1997;44:1419-25. [pmid: 9356866].
Bunout D, Hirsch S, Petermann M, et al. [Controlled study of the effect of silymarin on alcoholic liver disease].[Spa]. Rev Med Chil. 1992;120:1370-5. [pmid: 1343377].
Trinchet JC, Coste T, Levy VG, et al. [A randomized double blind trial of silymarin in 116 patients with alcoholic hepatitis]. [Fre]. Gastroenterol Clin Biol. 1989;13:120-4. [pmid: 2707520].
Pares A, Planas R, Torres M, et al. Effects of silymarin in alcoholic patients with cirrhosis of the liver: Results of a controlled, double-blind, randomized and multicenter trial. J Hepatol. 1998;28:615-21. [pmid: 9566830].
Salmi HA, Sarna S. Effect of silymarin on chemical, functional, and morphological alterations of the liver. A double-blind controlled study. Scand J Gastroenterol. 1982;17:517-21. [pmid: 6753109].
Feher J, Deak G, Muzes G, et al. [Liver-protective action of silymarin therapy in chronic alcoholic liver diseases]. [Hun]. Orv Hetil. 1989;130:2723-7. [pmid: 2574842].
Lang I, Nekam K, Deak G, et al. Immunomodulatory and hepatoprotective effects of in vivo treatment with free radical scavengers. Ital J Gastroenterol. 1990;22:283-7. [pmid: 1983711].
Fintelmann V. Zur Therapie der Fettleber mit Silymarin. Therapiewoche. 1970;20.
Fintelmann V, Albert A. [Double blind trial of silymarin sodium in toxic liver damage]. [Ger]. Therapiewoche. 1980;30:5589-94.
Tanasescu C, Petrea S, Baldescu R, et al. Use of the Romanian product Silimarina(R) in the treatment of chronic liver diseases. Rev Roum Med. 1988;26:311-22.
Ferenci P, Dragosics B, Dittrich H, et al. Randomized controlled trial of silymarin treatment in patients with cirrhosis of the liver. J Hepatol. 1989;9:105-13. [pmid: 2671116].
Benda L, Dittrich H, Ferenzi P, et al. [The influence of therapy with silymarin on the survival rate of patients with liver cirrhosis (author's transl)]. [Ger]. Wien Klin Wochenschr. 1980;92:678-83. [pmid: 7008367].
Marcelli R, Bizzoni P, Conte D, et al. Randomized controlled study of the efficacy and tolerability of a short course of IdB 1016 in the treatment of chronic persistent hepatitis. Eur Bull Drug Res. 1992;1:131-5.
Magliulo E, Gagliardi B, Fiori GP. [Results of a double blind study on the effect of silymarin in the treatment of acute viral hepatitis, carried out at two medical centres (author's transl)]. [Ger]. Med Klin. 1978;73:1060-5. [pmid: 353464].
Buzzelli G, Moscarella S, Giusti A, et al. A pilot study on the liver protective effect of silybinphosphatidylcholine complex (IdB1016) in chronic active hepatitis. Int J Clin Pharmacol Ther Toxicol. 1993;31:456-60. [pmid: 8225695].
Kiesewetter E, Leodolter I, Thaler H. [Results of two double-blind studies on the effect of silymarine in chronic hepatitis (author's transl)]. [Ger]. Leber Magen Darm. 1977;7:318-23. [pmid: 926982].
Palasciano G, Portincasa P, Palmier V, et al. The effect of silymarin on plasma levels of malon-dialdehyde in patients receiving long-term treatment with psychotropic drugs. Curr Ther Res Clin Exp. 1994;55:537-45.
Magula D, Galisova Z, Iliev N, et al. [Effect of silymarine and Fumaria alkaloids in the prophylaxis of drug-induced liver injury during antituberculotic treatment]. [Slo]. Stud Pneumol Phtiseol. 1996;56:206-9.
Allain H, Shuck S, Lebreton S, et al. Aminotransferase levels and silymarin in de novo tacrine-treated patients with alzheimer's disease. Dement Geriatr Cogn Disord. 1999;10:181-5. [pmid: 10325444].
Blumenthal M (National Advisory Panel Member). Personal communication from Mark Blumenthal, Dec 1999, who cited: Personal communication from Madaus through E. Leng-Peschlow and A. Strenge-Hesse, Nov 1999.
Vailati A, Aristia L, Sozze E, et al. Randomized open study of the dose-effect relationship of a short course of IdB 1016 in patients with viral or alcoholic hepatitis. Fitoterapia. 1993;64:219-28.
De Smet PA. An introduction to herbal pharmacoepidemiology. J Ethnopharmacol. 1993;38:197-208. [pmid: 8510469].
Andrade RJ, Lucena MI, De la Cruz JP, et al. Hepatology 1998;28:629A.
Albrecht M, Frerick H, Kuhn U, et al. [Therapy of toxic liver disease with Legalon(R)]. [Ger]. Z Klin Med. 1992;47:87-92.
Grungreiff K, Albrecht M, Strenge-Hesse A. [Benefit of medicinal liver therapy in general practice]. [Ger]. Med Welt. 1995;46:222-7.
Studlar M. [Treatment of chronic liver disease with silymarin plus B-group vitamins]. [Ger]. Therapiewoche. 1985;35:3375-8.
Frerick F, Kuhn U, Strenge-Hesse A. Silymarin-ein Phytopharmakon zur Behandlung toxischen Leberschäden: Anwendungsbeobachtung bei 2169 Patienten. Kassenarzt. 1990;33:36-41.
Schuppan D, Strosser W, Burkard G, et al. [Influence of Legalon(TM) 140 on the metabolism of collagen in patients with chronic liver disease-Review by measurement of PIIINP-values]. [Ger]. Z Allgemeinmed. 1998;74:577-84.
Marena C, Lampertico M. Preliminary clinical development of silipide: A new complex of silybin in toxic liver disorders [abstract]. Planta Med. 1991;57:124-5.
Geier J, Fuchs TH, Wahl R. [Anaphylactic shock due to an extract of Silybum marianum in a patient with immediate-type allergy to Kiwi fruit]. [Ger]. Allergologie. 1990;13:387-8.
Mironets VI, Krasovskaia EA, Polishchuk II. [A case of urticaria during carsil treatment]. [Rus]. Vrach Delo. 1990;7:86-7. [pmid: 2238610].
De Smet PA, Van den Eertwegh AJ, Lesterhuis W, et al. Hepatotoxicity associated with herbal tablets. BMJ. 1996;313.
Wollemann G, Seifert HU, Borelli S. Berufsbedingte Rhinokonjunktivitis auf Mariendistelsamen (Silybum marianum L.). Allergologie. 1987;10:505-7.
Adverse Drug Reactions Advisory Committee. An adverse reaction to the herbal medication milk thistle (Silybum marianum). Med J Aust. 1999;170:218-9. [pmid: 10092919].
Muzes G, Deak G, Lang I, et al. [Effect of silimarin (Legalon) therapy on the antioxidant defense mechanism and lipid peroxidation in alcoholic liver disease (double blind protocol)]. [Hun]. Orv Hetil. 1990;131:863-6. [pmid: 2345633].
Feher J, Lengyel G, Blazovics A. Oxidative stress in the liver and biliary tract diseases. Scand J Gastroenterol Suppl. 1998;228:38-46. [pmid: 9867111].
Boari C, Montanari FM, Galletti GP, et al. [Toxic occupational liver diseases. Therapeutic effects of silymarin]. [Ita]. Minerva Med. 1981;72:2679-88. [pmid: 7290471].
Bode JC, Schmidt U, Durr HK. [Silymarin for the treatment of acute viral hepatitis? Report of a controlled trial (author's transl)]. [Ger]. Med Klin. 1977;72:513-8. [pmid: 840125].
Cavalieri S. [Controlled clinical trial of silymarin in 40 patients]. [Ita]. Gazz Med Ital. 1974;133:628-35.
Del Dotto M, Neri D. [Alcoholic hepatopathy. Aspects of drug therapy]. [Ita]. G Clin Med. 1982;63:228-36. [pmid: 7128979].
De Martiis M, Barlattani A, Parenzi A, et al. [Relationship between changes of lipid metabolism and macrocytic anemia in the course of chronic liver disease. Evaluation of treatment with a membranotropic agent]. [Ita]. Clin Ter. 1984;111:135-9. [pmid: 6239735].
De Martiis M, Fontana M, Assogna G, et al. [Milk thistle (Silybum marianum) derivatives in the therapy of chronic hepatopathies]. [Ita]. Clin Ter. 1980;94:283-315. [pmid: 7004762].
Fintelmann V. [Postoperative behavior of serum cholinesterase and other liver enzymes]. [Ger]. Med Klin. 1973;68:809-15. [pmid: 4724028].
Lirussi F, Nassuato G, Orlando R, et al. Treatment of active cirrhosis with ursodeoxycholic acid and a free radical scavenger: A two year prospective study. Med Sci Res. 1995;23:31-3.
Roveda S, Colombo P, Pulvirenti A. [Evaluation of the efficacy and tolerance of silybin in the treatment of organic and functional diseases of the liver parenchyma]. [Ita]. Arch Med Int. 1991;43:97-102.
Saba P, Mignani E, Pagliai, et al. [Efficacy of silymarin treatment of acute virus hepatitis]. [Ita]. Epatologia. 1979;25:277-81.
Schopen RD, Lange OK. [Therapy of hepatoses. Therapeutic use of Silymarin]. [Ger]. Med Welt. 1970;15:691-8. [pmid: 5523243].
Szilard S, Szentgyorgyi D, Demeter I. Protective effect of Legalon in workers exposed to organic solvents. Acta Med Hung. 1988;45:249-56. [pmid: 3073356].
Tkacz B, Dworniak D. [Sylimarol in the treatment of acute viral hepatitis]. [Pol]. Wiad Lek. 1983;36:613-6. [pmid: 6353775].
Velussi M, Cernigoi AM, Viezzoli L, et al. Silymarin reduces hyperinsulinemia, malondialdehyde levels, and daily insulin need in cirrhotic diabetic patients. Curr Ther Res Clin Exp. 1993;53:535-45.
Velussi M, Cernigoi AM, De Monte A, et al. Long-term (12 months) treatment with an anti-oxidant drug (silymarin) is effective on hyperinsulinemia, exogenous insulin need and malondialdehyde levels in cirrhotic diabetic patients. J Hepatol. 1997;26:871-9. [pmid: 9126802].