# Methodology

This section describes methods used to identify key questions; literature search, retrieval, and selection strategies; and processes used for abstracting and analyzing studies.

## Expert Input

We owe a major debt of gratitude to the following groups of multidisciplinary experts from around the world who assisted in preparing this report: 10 national advisory panel members and 3 technical experts who helped define the scope and shape the content, 14 peer reviewers representing a variety of backgrounds and viewpoints, 5 scientific authors who provided additional data from their studies, and 12 staff members of the San Antonio Evidence-based Practice Center and the San Antonio Veterans Evidence-based Research, Dissemination, and Implementation Center, a Veterans Affairs Health Service Research and Development Center of Excellence. Their names are listed in the "Appendix C. Contributors" section of this report.

## Questions Addressed in Evidence Report

The national advisory and technical expert panels used the evidence model (Figure 1) and a modified Delphi process to identify clinically important questions that the evidence report should address (Table 1). Per the evidence model (see Figure 1), liver disease could be of viral, alcohol, toxin, or malignancy etiologies. The spectrum of level of disease included acute, chronic, cirrhosis (compensated), and liver failure (decompensated cirrhosis or fulminant toxic or viral disease).

Table 1. Key questions and selection criteria for evidence

Questions About Efficacy | Selection Criteria
1. In adults with alcohol-related liver disease (acute, chronic, cirrhosis, or liver failure), does oral ingestion of milk thistle supplements compared with no supplement, placebo, other oral supplements, or drugs alter physiologic markers of liver function, reduce mortality or morbidity, or improve quality of life? 2. In adults with viral hepatitis or its sequel (acute viral hepatitis, chronic active viral hepatitis, cirrhosis, or liver failure), does oral ingestion of milk thistle supplements compared with no supplement, placebo, other oral supplements, or drugs alter physiologic markers of liver function, reduce mortality or morbidity, or improve quality of life? 3. In adults with toxin- or drug-induced (other than alcohol) liver disease (acute, chronic, cirrhosis, or liver failure), does oral ingestion of milk thistle supplements compared with no supplement, placebo, other oral supplements, or drugs alter physiologic markers of liver function, reduce mortality or morbidity, or improve quality of life? 4. In adults with cholestasis (pregnancy-related or not pregnancy-related), does oral ingestion of milk thistle supplements compared with no supplement, placebo, other oral supplements, or drugs alter physiologic markers of liver function, reduce mortality or morbidity, or improve quality of life? 5. In adults with primary hepatic malignancy (hepatoma or cholangiocarcinoma), does oral ingestion of milk thistle supplements compared with no supplement, placebo, other oral supplements, or drugs alter physiologic markers of liver function, reduce mortality or morbidity, or improve quality of life? 6. Do different preparations vary in effectiveness regarding the above disease states and outcomes? | Study type: Initially, randomized controlled trial, then changed to any prospective controlled trial. Participants: Humans Intervention group: Supplemental milk thistle Control group: Placebo, no supplement, other oral supplements, drugs Outcomes (physiologic): Laboratory or histologic assessment of in vivo liver function Outcomes (clinical): Morbidity, mortality, hospitalization, quality of life, symptoms, Child's score (a score or classification system for chronic liver disease)
Questions About Chemical Profiling | Selection Criteria
1. What are the constituents of commonly available preparations of silymarin that have been used in studies? | Study type: Chemical profiling
Questions About Harms | Selection Criteria
1. What are the common symptomatic adverse effects of milk thistle, and what is their frequency? 2. What common serious adverse effects of milk thistle have been established for standard doses or large single doses, and what is their frequency? 3. What uncommon serious adverse effects of milk thistle have been established for standard doses or large single doses, and what is their frequency? | Study type: Randomized controlled trial, cohort study, case series study, or case report Participants: Humans Intervention group: Supplemental milk thistle Control group: Not required Outcomes: Any reported adverse effect Outcomes (clinical): Morbidity, mortality, hospitalization, quality of life, symptoms, Child's score

Cholestatic liver disease and primary malignancy were included in the evidence model and questions to be addressed because, a priori, we did not know if there would be evidence available for review. The final questions and types of studies deemed appropriate to answer the questions (selection criteria) are given in Table 1.

## Literature Search and Selection Methods

### Sources and Search Methods

English and non-English citations were identified to July 1999 from the electronic databases cited in Table 2; references of pertinent articles and reviews; Madaus, Germany; and technical experts. An update search limited to PubMed was conducted in December 1999. Database searching used maximally sensitive strategies to identify all papers on milk thistle and treatment or prevention of liver disease. Titles, abstracts, and keyword lists of the 11 sources in Table 2 were searched using the following terms that include Latin names for milk thistle and its constituents (".tw" indicates text word searches, "/" indicates key word searches, and "$" indicates a truncation within a text word). Search strategies are included in Appendix A.

Table 2. Electronic sources searched

Electronic Database | Description
AMED (Alternative and Allied Medicine Database) Searched from 1985 to October 1998 | This database contains 100,000 references from 400 journals on alternative and complementary medicine going back to 1985.
CINAHL (Cumulative Index to Nursing and Allied Health Literature Searched from 1984 to July 1999 | This database includes citations from over 500 biomedical and popular sources, including National League of Nursing and American Nurses Association publications, covers publications from 1982 to the present, and is considered the premier nursing database.
CISCOM (Centralised Information Service for Complementary Medicine) Searched 1968 to July 1999 | This database contains over 34,000 references and combines data from MEDLINE, AMED, and other specialist European databases.
Cochrane Library (http://www.cochrane.org ) DARE (Database of Reviews of Effectiveness) (http://www.york.ac.uk/inst/crd/ ) The Cochrane Controlled Trials Registry Searched Issue 2 1999 | These databases contain references of randomized controlled trials and systematic reviews identified from electronic bibliographic sources and hand searching of multiple journals and symposia or meeting proceedings.
Dissertation Abstracts Searched from 1961 to December 1998 | This library indexes doctoral dissertations and masters abstracts from more than 1,000 institutions.
EMBASE Searched from 1988 to July 1999 | This database contains biomedical and pharmaceutical citations and is considered the premier biomedical database in Europe.
MEDLINE (PubMed) Searched from 1966 to July 1999 PubMed searched July 1999 to November 1999 | These databases (MEDLINE and PubMed) index almost 4,000 international biomedical journals from 1966 to the present, includes references from Index Medicus, International Nursing Index, and Index to Dental Literature, and is considered the premiere biomedical database in the United States.
MICROMEDEX contains: DRUGDEX Product Index (drug ingredients) POISONDEX/IDENTIDEX (toxicology) DRUG-REAX (interactive drug interactions) Searched July 1999 | This database provides a major source for drug, poison, and acute care information.
NAPRALERT (Natural Products Alert) Searched September 1999 | This database contains records from 1650 to the present on natural products, including the pharmacology, biologic activity, taxonomic distribution, ethno-medicine and chemistry of plant, microbial, and animal extracts.
PHYTODOK (German Database) Searched 1995 to July 1999 | This database contains 8,800 references from approximately 300 journals worldwide on toxicology, pharmacology, and therapeutic uses for natural compounds and on isolation of natural compounds from plant material.
Science Citation Index Searched from January 1990 to March 1999 | This index covers 4,400 scientific and 1,400 social science journals worldwide, together with selected coverage of related material.

Sources and Search Methods

carduus marianus.tw. | milkthistle$.tw. | silydianin$.tw.
legalon$.tw. | sily$.tw. | silymarin$.tw.
mariendistel.tw. | silybin$.tw. | silymarin$/
milk thistle$.tw. | silybum marianum.tw. | silymarin.tw.
milk-thistle$.tw. | silybum$.tw. | silymarin/
milk-thistle$.tw. | silychristin$.tw.

After these materials were reviewed and relevant studies obtained and abstracted, an updated search to November 1, 1999, was conducted using MEDLINE and EMBASE.

### Selection Processes

At least two independent reviewers scanned the titles and abstracts of all records identified from the search using the selection criteria given in Table 1. For each formulated question, selection criteria specified the types of participants, interventions, control groups, outcomes, and study designs that were deemed appropriate. Figure 2 schematically presents the selection process. Of 1,727 records, reviewers excluded 1,505 with certainty when screening titles and abstracts. Most of these were in vitro studies, involved animals, did not provide primary data regarding effectiveness, were duplicate reports, or did not meet design inclusion criteria. When the full texts of the remaining 215 (7 were unobtainable) were screened, 164 more were excluded for the same reasons. Of the 51 records meeting selection criteria, 33 were prospective trials, and 18 were reports of adverse effects.

Figure 2. Selection process

Initially, we planned to limit efficacy evidence to randomized controlled trials (RCTs) comparing milk thistle with placebo, no milk thistle, or another active agent. Ultimately, we included evidence from prospective placebo-controlled trials or cohort studies for several reasons. First, there were scant data, and it was thought that evidence from studies other than randomized trials might provide useful preliminary information. Second, several reportedly "randomized" trials had dissimilar numbers of subjects among the study arms, raising the possibility that they were not randomized and not of significantly different quality than other prospective controlled studies. The search for evidence was not repeated at the point that selection criteria were broadened, because the search had been designed to detect all studies of milk thistle regardless of their design.

## Data Abstraction Process

Two independent persons with clinical and methodologic expertise abstracted data; they were not blinded either to study titles or to authors'names. Previous research indicates such blinding does not enhance validity of results, and it is time and labor intensive to prepare fully masked publications. ^55^ Items related to the internal validity of studies that were assessed included whether the trial was randomized, adequacy of randomization (method and concealment of assignment), whether the trial was single or double blind, whether intervention and control groups were adequately matched, identification of cointerventions such as diet or other medications, and the number of dropouts. Disagreements in abstractions were resolved by consensus. Formal quality scores were not done because of controversy as to how to handle and weight such scores statistically. Elements of study quality are given in the evidence tables. If not known, then no information or "not given" is noted in the evidence tables. After the abstraction training phase, no further reliability assessment was conducted.

One research nurse and one physician with expertise in methodology abstracted studies addressing adverse effects. Items addressing adverse effects that were abstracted included study design (case report, case series, case control, cohort, controlled trial) and type of specific adverse effect. Several explicit criteria aimed at assessing drug adverse effect causality were assessed, including appropriate temporal relationship, lack of apparent alternative causes, known toxic concentrations of the drug at the time of the appearance of the symptom, disappearance of the symptom with drug discontinuation, dose-response relationship, and reappearance of the symptom if the drug was readministered. ^56^

### Unpublished Data

For reports published as abstracts, we excluded those for which we were unable to identify a complete subsequent publication by a repeat search of MEDLINE and EMBASE for any of the abstract authors. When published studies met selection criteria but did not report important design features or outcome data, this unpublished information was requested from the authors.

### Data Analysis Process

Data were synthesized descriptively, emphasizing methodologic characteristics of the studies, such as populations enrolled, definitions of selection and outcome criteria, sample sizes, adequacy of randomization process, interventions and comparisons, cointerventions, biases in outcome assessment or intervention administration, and study designs. Relationships between clinical outcomes, participant characteristics, and methodologic characteristics are presented in evidence tables and graphic summaries such as forest plots.

Primary outcomes in studies were measured with continuous rather than categorical variables. We used the standardized mean differences between treatment and comparison group scores as the effect size measure for each study. Hedges' g was used to compute the standardized mean difference for each trial:

[image]

where, for a given trial [image] are the mean clinical outcome scores for the treatment group and comparison group, respectively; s _pooled_ is the pooled standard deviation for the difference between the two means. ^57^ These estimates were adjusted for between-group differences at baseline and for small sample bias. ^57^ Adjustment for baseline differences was accomplished by calculating an "effect size" at baseline; by definition, it should be zero if study groups were well matched. When a nonzero "effect size" at baseline was found, outcome effect sizes were adjusted by subtracting the baseline effect size.

Published reports seldom provided estimates of S _pooled_ One of three strategies was used to estimate S _pooled_ when the authors did not directly provide it. First, the individual group variances were used to estimate S _pooled_ If these data were not reported, the pooled variance was back-calculated from either the test statistic or the p value for differences at followup. ^58^ If neither was possible, a mean variance derived from studies of similar size was used. Studies in which the pooled variance was calculated using either of the two latter methods were flagged in the event the magnitude of the effect size resulted in the study being identified as a potential outlier in the analysis of heterogeneity.

### Exploratory Meta-Analysis

Meta-analysis was used as an exploratory tool to help identify patterns of findings. Prospective placebo-controlled randomized trials using albumin, bilirubin, aspartate aminotransferase (AST), alanine aminotransferase (ALT), gammaglutamyl transpeptidase (GGTP), malondialdehyde (MDA), alkaline phosphatase (alk phos), prothrombin time (PT), Child's score (a score or classification system for chronic liver disease), and histologic and survival outcomes were quantitatively pooled by clinical outcome using meta-analysis. Subgroup analyses were conducted for trials that included patients with the following: chronic alcoholic liver disease, acute viral liver disease, chronic viral liver disease, mixed liver disease (all chronic), cirrhosis, and alcoholic cirrhosis.

We adopted the DerSimonian and Laird random-effects model to estimate the pooled measures of treatment efficacy. ^59^ ^60^ If there is no substantial heterogeneity among the trials, the random-effects estimator reduces to the classical fixed-effects estimate. When significant heterogeneity exists, the random-effects model incorporates the statistical heterogeneity into the summary estimate and confidence interval. The random-effects model confidence interval is wider than the fixed-effect model confidence interval, when substantial heterogeneity exists, making the random-effects model more conservative.

Heterogeneity among trials was tested with a standard chi-square test (using a p value greater than 0.1 as evidence of heterogeneity), Galbraith plots, and funnel plots. A Galbraith plot is a graphic method used to complement the statistical assessment of heterogeneity and is particularly useful when the number of studies is small. ^60^ The position of each study along the two axes gives an indication of the weight allocated in the meta-analysis. The vertical axis (a Z statistic equal to the effect size divided by its standard error) gives the contribution of each study to the Q (heterogeneity) statistic. Points outside the confidence bounds are those studies that have a major contribution to heterogeneity; in the absence of heterogeneity, all points would be expected to be within the confidence bounds. Funnel plots used Begg's rank order correlation test. ^61^ STATA 6.0 ^®^ (STATA Corporation ^®^ ) was used to perform all analyses and produce the graphic output. ^62^ Specifically, the meta command was used to compute and graph the random-effects model estimates, ^63^ the "galbr" command to assess heterogeneity and produce Galbraith plots, ^62^ and the metabias command to examine publication bias. ^64^

Effect sizes were converted to clinical laboratory units to aid in interpreting effect-size standard deviation units. As noted above, the effect-size statistic is calculated by dividing the between-group difference by the pooled standard deviation of the two groups. Since both numerator and denominator are expressed in the original laboratory units (e.g., milligrams per deciliter [mg/dL]), the units cancel out, and the effect size statistic is therefore "unitless." Effect sizes can be back-converted to a clinical laboratory value expressed in the original unit (e.g., mg/dL) by multiplying the effect-size value by a standard-deviation value. The statistical significance of the values (effect sizes or converted values) does not change; however, the magnitude of the "converted effect" will vary up or down depending on the magnitude of the standard deviation used.

Conversion of effect sizes to clinical laboratory units should not be interpreted as "true" values; conversions are presented for the single purpose of enhancing the interpretation of effect-size standard-deviation units.

Lacking population standard-deviation values (if available, they could be used), the investigator chose to use the "average" standard-deviation value for the pooled studies within each group. Two "averages" were examined: a weighted pooled standard deviation across studies (weighted by sample size) and the median pooled standard deviation. When the two values were substantially different (representing skewness), the median value was chosen. When the values were similar (or when only two studies provided pooled standard deviation estimates), the weighted pooled standard deviation value was used to convert effect sizes. Weighted average standard deviations that were used to convert effect sizes to clinical laboratory units were: albumin (0.74 grams per deciliter [g/dL]), bilirubin (0.32 g/dL), aspartate aminotransferase (44.77 units per liter [U/L]), alanine aminotransferase (36.02 U/L), gammaglutamyl transpeptidase (153.94 U/L), malondialdehyde (6.65 millimoles per milliliter [mmol/mL]), alkaline phosphatase (101.01 U/L), prothrombin time (17.40 seconds), and Child's score (2.55 units).