# Appendix D. Acronyms

- ALT
- alanine aminotransferase

- AST
- aspartate aminotransferase

- GGTP
- gammaglutamyl transpeptidase

- HBV
- hepatitis B virus

- HCV
- hepatitis C virus

- HIV
- human immunodeficiency virus

- HPLC
- high performance liquid chromatography

- MDA
- malondialdehyde

- PT
- prothrombin time

- RCT
- randomized controlled trial

- RNA
- ribonucleic acid

- TLC
- thin-layer chromatography