# Appendix C. Contributors

We owe a major debt of gratitude to the following groups of multidisciplinary experts from around the world who assisted in preparing this report: 10 national advisory panel members, 3 technical experts who helped define the scope and shape the content, 14 peer reviewers representing a variety of backgrounds and viewpoints, and 5 scientific authors who provided additional data from their studies.

## National Advisory Panel

Marilyn Barrett, PhD Owner and Principal Pharmacognosy Consulting Services

Mark Blumenthal Executive Director American Botanical Council

David Eisenberg, MD Beth Israel Deaconess Medical Center

Lucinda Miller, PharmD, BCPS Editor Journal of Herbal Pharmacotherapy

Richard Nahin, MPH, PhD Acting Director Division of Extramural Research National Center for Complementary and Alternative Medicine

Mary Ann Richardson, DrPH Assistant Professor and Director The University of Texas Center for Alternative Medicine Research in Cancer The University of Texas - Houston Health Science Center School of Public Health

Nancy Ridenour, RN, PhD, CS, FNC, FAAN Dean College of Nursing Illinois State University

David Schardt Associate Nutritionist Center for Science in the Public Interest

William A. Watson, PharmD, DABAT, FAACT Professor (Clinical) and Managing Director Department of Surgery South Texas Poison Center The University of Texas Health Science Center at San Antonio

Elizabeth Yetley, PhD Director Office of Special Nutritionals Center for Food Safety and Applied Nutrition Food and Drug Administration

## Technical Experts

Bradly Jacobs, MD, MPH Senior Clinical Research Fellow Osher Center for Integrative Medicine Department of Medicine University of California - San Francisco/Veterans Affairs Medical Center

Cathi Dennehy, PharmD Assistant Clinical Professor University of California at San Francisco

Kenneth Flora, MD, FACG Assistant Professor Oregon Health Sciences University

## Peer Reviewers

Fourteen peer reviewers provided insightful comments and feedback on our draft report.

Maurizio Bonacini, MD Associate Professor Hepatitis Research Center Division of Gastroenterology and Liver Diseases Department of Medicine University of Southern California School of Medicine

Robert Eckel, MD Professor Division of Endocrinology, Metabolism, and Diabetes Department of Medicine University of Colorado Health Science Center

Wolfgang Fleig, MD Professor and Chair First Department of Medicine Martin Luther University Halle-Wittenberg Halle (Saale), Germany

Robert Fontana, MD Assistant Professor Department of Internal Medicine University of Michigan Health System

Alexander Gerbes, MD Professor Ludwig-Maximilians-Universitat-München

Eric Gershwin, MD Division Chief Division of Rheumatology/Allergy Department of Internal Medicine University of California at Davis School of Medicine

Ruth Kava, PhD, RD Director of Nutrition American Council on Science and Health

Ronald Koretz, MD Professor and Chief Division of Gastroenterology Department of Medicine University of California at Los Angeles

David Lee, PhD Director Natural Products Laboratory McLean Hospital

Klaus Linde, MD Researcher Centre for Complementary Medicine Research Department of Internal Medicine II Technichal University

Tianshu Liu, MD, MSc Attending Physician Department of Gastroenterology Shanghai Medical University Zhoug Medical Hospital

Srini Srinivasan, PhD Director Dietary Supplements Division U.S. Pharmacopoeia

Kathleen Stevens, RN, EdD, FAAN Professor Department of Family Nursing The University of Texas Health Science Center at San Antonio

Wendell Winters, PhD Associate Professor Department of Microbiology The University of Texas Health Science Center at San Antonio

## Authors Who Provided Additional Data

Some articles included in this report had relevant data missing from their publications. We contacted the authors requesting this information. Our heartfelt thanks to those who responded:

- Dr. Paolo Saba
- Dr. Heikki A. Salmi
- Dr. Gianluigi Vendemiale
- Dr. Peter Ferenci
- Dr. Robert Flisiak

## San Antonio Evidence-based Practice Center and Veterans Evidence-based Research, Dissemination and Implementation Center Staff

### Project Leaders

Cynthia Mulrow, MD, MSc Program Director

Valerie Lawrence, MD, MSc Principal Investigator

### Project Investigators

Valerie Lawrence, MD, MSc Cynthia Mulrow, MD, MSc Bradly Jacobs, MD, MPH Cathi Dennehy, PharmD Jodi Sapp, RN Christine Aguilar, MD, MPH Kelly Montgomery, MPH Laura Morbidoni, MD Elaine Chiquette, PharmD Kenneth Flora, MD, FACG

### Meta-Analysts

Gilbert Ramirez, DrPH John E. Cornell, PhD

### Information Specialists

Andrew Vickers, MD Martha Harris, MLS, MA

### Technical Writer and Peer Review Coordinator

Jennifer Moore Arterburn, MTSC

### Computer Resources

David Mullins

### Administration

Annie Almanza Sheryl Moore Linn Morgan