# Appendix A. Milk Thistle Search Strategies

All papers MEDLINE

Date: 18-Jun-1999

Name: sily1, sily2, sily3, sily3a, sily4 (SAVED AS SILYMEDL)

Database: Medline <1966 to present>

Appendix A. Milk Thistle Search Strategies

Set | Search | Results
001 | exp liver diseases/ | 201649
002 | exp medicine, herbal/ | 1079
003 | 1 and 2 | 36
004 | legalon.tw. | 34
005 | silymarin.tw. | 277
006 | silybin.tw. | 120
007 | mariendistel.tw. | 0
008 | carduus marianus.tw. | 5
009 | milk thistle.tw. | 19
010 | milkthistle.tw. | 0
011 | silybum marianum.tw. | 46
012 | 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 | 441
013 | limit 12 to french | 17
014 | limit 12 to german | 87
015 | limit 12 to italian | 15
016 | silymarin$/ | 393
017 | 16 or 12 | 530
018 | silydianin.tw. | 13
019 | silychristin.tw. | 9
020 | 17 or 18 or 19 | 530
021 | silybum.tw. | 49
022 | silymarin$.tw. | 289
023 | silybin$.tw. | 128
024 | milk thistle$.tw. | 19
025 | milk-thistle$.tw. | 19
026 | 20 or 21 or 22 or 23 or 24 or 25 | 537
027 | sily$.tw. not 26 | 587
028 | 27 and 1 | 2
029 | liver.tw. | 285638
030 | 29 and 27 | 19
031 | 2 and 29 | 31
032 | 31 or 26 | 555
033 | amanita phalloides.tw. | 323
034 | 33 and 2 | 0
035 | 32 | 555

All papers EMBASE

Date: 18-Jun-1999

Name: silyem1

Database: EMBASE <1988 to present>

Appendix A. Milk Thistle Search Strategies

Set | Search | Results
001 | exp clinical trials/ | 152066
002 | (clin$ adj25 trial$).ti,ab. | 41418
003 | (((singl$ or doubl$ or trebl$ or tripl$) adj25 blind$) or ma | 46401
| sk$).ti,ab.
004 | placebo$.ti,ab. | 40081
005 | random$.ti,ab. | 121458
006 | or/1-5 | 281333
007 | (animal not human).sh. | 643
008 | 6 not 7 | 281326
009 | comparative study.sh. | 2801
010 | exp evaluation studies/ | 88844
011 | (control$ or prospectiv$ or volunteer$).ti,ab. | 597231
012 | or/9-11 | 669129
013 | 12 not 7 | 669060
014 | 12 not 8 | 557713
015 | 8 or 14 | 839039
016 | silymarin$.tw. | 184
017 | legalon$.tw. | 69
018 | silymarin/ | 353
019 | silybin$.tw. | 75
020 | silydianin$.tw. | 3
021 | silychristin$.tw. | 1
022 | silybum$.tw. | 37
023 | milk-thistle$.tw. | 16
024 | milkthistle$.tw. | 0
025 | milk thistle$.tw. | 16
026 | exp herbal medicine/ | 2179
027 | exp liver disease/ | 93302
028 | 26 and 27 | 182
029 | 28 and 15 | 35
030 | or/16-25 | 431
031 | 30 or 29 | 464
032 | 31 | 464