# Appendixes

Appendix A. Milk Thistle Search Strategies

Appendix B. Graphic Summaries

Appendix C. Contributors

Appendix D. Acronyms