# Results

The literature search yielded 1,998 unique citations. In total, 1,303 (65 percent) were excluded from further review following the initial level of title and abstract screening. Because of the complexity of the content area, and challenges in defining the ‘clinical relevance’ of the reported evaluations, full text screening was conducted in three phases. The first phase was conducted by EPC staff and focused on the most straightforward assessment of the overall study against eligibility criteria; the second phase was conducted by investigators and focused on establishing the eligibility of the specific SNPs within the panel reported; the third phase was also conducted by the investigators and focused on deciding whether the SNP panel could be considered ‘available’ and whether the evaluation context could be considered, at least to some extent, clinically relevant. Therefore, out of the 695 citations promoted to full text screening, 457 were excluded at the first phase, 127 were excluded at the second phase, and 97 at the third phase. This left 14 articles 188-201 retained for the review, which proceeded to data abstraction and quality assessment. All 14 focused on the assessment of clinical validity (KQ2). Figure 2 depicts the flow of studies through the screening process, and reasons for study exclusion. The remainder of this chapter describes the evidence for the key questions (KQs) and a quality assessment of the studies.

Figure 2 Flow diagram depicting the flow of studies through the screening process

Figure 2 is a flow diagram indicating the numbers of citations included and excluded at each level of screening. In addition the reasons for exclusion at full text screening and sorting are included. The literature search yielded 1,998 unique citations. In total, 1,303 citations were excluded from further review following the initial level of title and abstract screening. Out of the 695 citations promoted to the initial level of full text screening, 454 were excluded and 238 proceeded to full text sorting. Of the 238 articles sorted, 127 were excluded. The remaining 111 citations were subject to full text panel screening where 97 were excluded. This left 14 articles that passed full text screening and proceeded to data extraction and quality assessment.

One challenge that became evident during the assembly of source material for review was a lack of published data describing the technical protocols and analytical accuracies achieved for specific SNPs, and in particular, their analytical validation. There was also a paucity of information describing the laboratory protocols used to demonstrate the analytical validation of SNP panels used for clinical service testing. The reviewers sought but did not receive additional unpublished details about the analytical and clinical validation of proprietary commercial panels from the providers of these services. Therefore, from the articles eligible for KQ2 (clinical validity), we abstracted any information that was relevant to KQ1 (analytic validity).

## Characteristics of the Studies

All but two of the studies were of case-control design with the number of cases ranging from 203 to 2,899 and the number of controls from 560 to 1,781 (Tables 8 through 10). One study was a cross-sectional study of 5,241 men who had undergone prostate biopsy,200 and one was an investigation of survival in 2,875 men diagnosed with prostate cancer.201 The studies were carried out in Canada,195 Sweden,188,192,198,200,201 the United States,189,191,194,196,197,199 (clarified in an email from W. Catalona, M.D. ( WCatalona@nmff.org) in February 2012) and in both Sweden and the United States.190,193

Table 8 Characteristics of included studies

Author Year | Study Objective Study Design | Setting Location Dates of Data Collection | Study Participants Eligibility Source and Method of Selection Number Assessed for Eligibility
Aly200 2011 | Model development Cohort | 5,241 men who underwent prostate biopsy Stockholm, Sweden 2005 - 2007 | Exclusion: age >80, deceased, no valid personal number or address, other cancer than prostate at biopsy, known prostate cancer before 2005, lack of consent Patient registries in 2 of 3 pathology departments in Stockholm, Sweden 8,088 identified, 7,035 invited, 5,241 accepted
Beuten196 2009 | Model development Case-control | Screening center funded by national cancer institute Texas, U.S. NR but screening center opened in 2001 | Cases had biopsy confirmed prostate cancer. 231 incident cases from San Antonio Center for Biomarkers of Risk of Prostate Cancer cohort + 655 prevalent cases; controls volunteers >45 years normal DRE and PSA <2.5ng/mL on all study visits 1,452 non-Hispanic Caucasians (cases = 609 , controls = 843); 709 Hispanic Caucasians (cases = 195, controls = 514); 291 African-Americans (cases = 82, controls = 209)
Helfand191 2010 | Model Development Case-control | Hospital cases (90% treated by single surgeon); volunteer control group previously described matched on European descent Chicago, U.S. June 2002 - May 2008 (biopsy and pathological findings prospectively collected in cases) | Inclusion: European descent, with CaP who underwent radical prostatectomy at Northwestern Memorial Hospital Exclusion: lack of genetic data and/or incomplete clinical information Consecutive men with CaP who underwent radical prostatectomy. Controls were volunteers (PSA less than 2.5ng/mL, and normal digital rectal exam) 1,614 men
Helfand199 2011 | Model development Case-control | 1,459 white men who underwent radical prostatectomy. 203 had normal screening examination at time of Dx, clinical stage T1C, PSA <4ng/mL and nonsuspicious DRE; Controls: 611 recruited as healthy control subjects for genetic studies from the national Prostate Cancer Coalition screening study (2007); controls had PSA<4.0ng/mL, normal DRE, no prior Hx of a prostate biopsy Washington University, St Louis, MO; and Northwestern University Chicago, IL. 97.5% treated by same surgeon 1997 - 2009 | NR NR 1,459
Nam195 2009 | Validation (models from Zheng, et al., 2008^188^) and model development Case-control | Recruited from prostate centers of the University of Toronto (Sunnybrook and Women's College Health Sciences Center and University Health Network) Toronto, Ontario, Canada. June 1999 - June 2007 | Cases= Inclusion: PSA values ≥4.0ng/mL or an abnormal DRE; All patients underwent 1 or more transrectal ultrasonography-guided needle core biopsies; Primary endpoint was histological presence of adenocarcinoma of the prostate in biopsy specimen based on Gleason score Exclusion: PSA >50ng/mL (where the decision to biopsy would be considered unequivocal), not capable of giving consent to participate in the study, could not provide sufficient baseline information, or had a Hx of CaP Controls= Inclusion: no inclusion criteria reported aside from no presence of histologic adenocarcinoma of the prostate from biopsy Exclusion: Hx of CaP Source: men who were part of a screening program, selection was based on biopsy confirmed CaP; Samples were obtained using a systematic pattern and additional targeted samples were taken of suspicious areas; Those with histological presence of adenocarcinoma of the prostate were cases, while those that were not were controls 3,108
Penney197 2009 | Model development Physician Health Study (PHS) labeled nested case-control but also referred to as a prospective cohort by authors Dana Farber Harvard Cancer Center SPORE (Gelb center) case series; No controls FHCRC King County Case-control; 2 population-based case-controls | PHS: Randomized controlled trial of aspirin and beta carotene U.S. Blood samples 1982 – 1984; Followup through March ,1 2008 Gelb Center: Referral hospital-based case series Boston, U.S. 1976 - 2007 FHCRC: 2 population-based case-control; Incident cases with histologically confirmed prostate cancer ascertained from Seattle SEER cancer registry King County, Washington, U.S. Study I: Jan 1, 1993 – Dec 31, 1996; Study II: Jan 1, 2002 – Dec 31, 2005 | PHS: Inclusion: Healthy U.S. physicians; Excluded at baseline if any serious medical conditions including all cancers except non-melanoma skin cancer; Restricted participation to self-reported Caucasians; Controls selected by risk-set sampling matched on age, smoking status & followup time; Caucasians only Self-reported prostate cancer cases verified through medical record and pathology review 1,438 Gelb Center: Inclusion: Healthy U.S. physicians; Excluded at baseline if any serious medical conditions including all cancers except nonmelanoma skin cancer; Restricted participation to self-reported Caucasians Self-reported prostate cancer cases verified through medical record and pathology review NR FHCRC: Inclusion: Healthy U.S. physicians; excluded at baseline if any serious medical conditions including all cancers except nonmelanoma skin cancer; Restricted participation to self-reported Caucasians Incident cases with histologically confirmed prostate cancer from SEER cancer registry Controls identified with one-step random digit dialing, matched by age; Only Caucasians included 2,448
Salinas189 2009 | Model development validation of Zheng188 Case-control | Cases recruited from Seattle-Puget SEER cancer registry Participants from King County, Washington, U.S. (study I and II) Study I: Jan 1, 1993 - Dec 31, 1996; Study II: Jan 1, 2002 - Dec 31, 2005 | Inclusion: Cases = histologically confirmed CaP from cancer registry, Caucasian Controls = residents of King County, no self-reported Hx of CaP, Caucasian Control selection: Residence of King County, without self-reported Hx of CaP, identified using a step random digit dialing frequently matched to cases by 5y age groups, recruited evenly throughout both ascertainment periods for case patients; Complete census information obtained for 94% and 81% of residential numbers contacted in Study I and II, respectively 2,244 CaP patients identified; 2,448 met control eligibility
Sun190 2008 | Model is validating previously reported model from Zheng, et al.188 Case-control | JHH: Samples from JHH (Baltimore, MD), 1999 - 2006 CGEMS: Cases and controls from PLCO cancer screening trial (United States), 1992 - 2008 CAPS: Cases = 4 regional cancer registries; Controls = Swedish Population Registry Sweden July 2001 - October 2003 | JHH: Cases = European-American men undergoing CaP treatment; Controls = European-American men undergoing CaP screening, >55 years of age, normal digital rectal exam, <4.0ng/mL PSA Cases = 1,562; Controls = 576 CGEMS: European-American men selected from PLCO Cancer Screening Trial using incidence density sampling strategy Cases = 1,172; Controls = 1,157 CAPS: Biopsy-confirmed or cytologically verified adenocarcinoma of the prostate, diagnosed between July 2001 and October 2003 Cases: 6 cancer registries; Method of selection apart from inclusion criteria not reported; Controls recruited concurrently and randomly selected from Swedish Population Registry Cases = 3,648; Controls = 3,153 Combined cumulative analysis (all three study populations): Cases = 5,628; Controls = 3,514
Sun194 2008 | Model development Case-control | HPC families were studied at Brady Urology Institute at Johns Hopkins Hospital; Non-HPC cases = same hospital; Controls = CaP screening from the hospital and greater Baltimore area. Baltimore, MD, U.S. HPC cases = described previously (Xu, et al., 2001^223^) Non-HPC = 1999 - 2006 | Cases: HPC case criterion = prostate cancer (CaP) patients who have at least 2 first degree relatives diagnosed with CaP; non-HPC case criteria = patients undergoing radical prostatectomy for treatment of CaP at Johns Hopkins Hospital between 1999 to 2006 with DNA samples indicating normal seminal vesicle tissues; European Ancestry inclusion criterion for all cases; Controls: normal DRE, PSA <4.0ng/mL, and older than 55 years of age; Quality control checks: HPC cases = CaP was verified by medical records for each affected male studied; non-HPC cases = tumors from each patient were graded and staged using uniform criteria established and implemented by a single pathologist HPC Cases = 221 index CaP patients (probands) of European ancestry met the HPC criterion, while 168 of these probands had DNA sampled from affected and nonaffected relatives for linkage; Non-HPC cases = not specified, however 1,404 were collected DNA samples isolated from normal seminal vesicle tissue; Controls = 560 met eligibility Number assessed NR
Sun198 2011 | Model development Cohort within a population case-control | Cases from regional cancer registries in Sweden, controls randomly selected from Swedish Population Registry and matched according to expected age distribution of cases (groups of 5 year intervals) and geographic region Sweden NR | Pathologically or cytologically verified adenocarcinoma of the prostate NR 2,899
Wiklund201 2009 | Model development Population-based case-control | CAPS: Cases = 4 of 6 regional cancer registries in Sweden Controls = Swedish population registry Sweden July 2001 - October 2003 | Histologically or cytologically verified adenocarcinoma of the prostate (ICD-10:C61) NR 2,875 Cases
Xu193 2009 | Model development and validation Case-control | CAPS: Cases = 4 of 6 cancer registries in Sweden Controls = Swedish population registry Sweden July 2001 - October 2003 PLCO: Independent Study Population from PLCO trial United States 1992 - 2009 | CAPS: Cases = 2,899; Controls = 1,722 PLCO: Cases = 1,172; Controls = 1,157
Zheng192 2009 | Model development and validation Case-control (CAPS study) | Cases = 4 of 6 cancer registries in Sweden Controls = Swedish population registry Sweden July 2001 - October 2003 | Case eligibility: Pathologic or cytologically verified adenocarcinoma of the prostate, Diagnosed between July 2001 and October 2003 Aggressive case eligibility: Consent to participate, T3/4, N+, M+, Gleason score sum ≥8, or PSA >50ng/mL; Otherwise they were classified as nonaggressive (localized) cases Control eligibility: consent to participate (PSA obtained but not used for exclusion) Cases: From 4 of 6 regional cancer registries in Sweden, method of selection not reported Controls: Recruited by invitation and randomly selected concurrently with case subjects, from Swedish Population Registry Cases = 3,648; Controls = 3,153
Zheng188 2008 | Model Development Case-control | Cases = 4 regional cancer registries;Controls = Swedish Population Registry Sweden July 2001 - October 2003 | Biopsy-confirmed or cytologically verified adenocarcinoma of the prostate, diagnosed between July 2001 and October 2003 Cases: 6 cancer registries; Method of selection apart from inclusion criteria not reported; Controls recruited concurrently and randomly selected from Swedish Cases = 3,648; Controls = 3,153

Abbreviations: CaP = prostate cancer; CAPS = cancer of the prostate in Sweden; CGEMS = cancer genetic markers of susceptibility; DNA = deoxyribonucleic acid; DRE = digital rectal examination; Dx = diagnosis; FHCRC = Fred Hutchinson cancer research center; GWA = genome-wide association; HPC = hereditary prostate cancer; Hx = history; JHH = Johns Hopkins Hospital; NR = not reported; PLCO = prostate lung cancer ovarian; PSA = prostate specific antigen; SEER = surveillance epidemiology and end results; SNP = single nucleotide polymorphism; SPORE = specialized programs of research excellence; y = year(s)

Table 9 Characteristics of included studies: SNPs

Author Year | SNP's Number genotyped and considered for inclusion in panel Was genotyping done blind to participant status? | Hardy Weinberg Equilibrium (HWE) Assessed? If yes, method? In controls? If no, in all participants? Result(s) [indicate whether this was for all SNPs considered for inclusion, or just those in the model(s) developed or evaluated | How were SNPs handled in analysis? (e.g., dominant or recessive effects per SNP, per allele, genotype categories, risk scores [explain which of alleles/genotypes is considered to be risk variant]) | Other variables included in SNP panel
Aly200 2011 | Cases = 2,135; Controls = 3,108 NR | HW calculations were performed to verify that each marker was within an allelic equilibrium in the control population. | NR | Nongenetic model included log total PSA, log free to total PSA ratio, age at biospy and family Hx of CaP. The genetic model also included the genetic risk score.
Beuten196 2009 | 2,452 samples NR | Checked for each SNP; rs6201 showed deviation from HW equilibrium in cases and controls of all 3 ethnic groups; In Caucasians, rs10923823 not in HW equilibrium in cases or controls and rs3751592 out of HW equilibrium in non-Hispanic Caucasians; SNPs not in HW equilibrium left out of further statistical analyses | OR and 95% CI was estimated by unconditional logistic regression as a measure of the association between genotype and CaP risk. Tested for additive, dominant, and recessive associations. Generalized linear model function with all SNPs were entered into a single multivariate logistic regression model (SNPs with additive effects). The random forest algorithm was applied. The generalized multifactor dimensionality reduction was also used. | NR
Helfand191 2010 | Cases = 687; Controls = 777 Was done elsewhere and previously described | Yes, but methods not shown; all genetic variants were in HWE. | Differences in alleles between cases and controls were tested for each SNP using a logistic regression model; CaP risk OR was estimated from regression coefficients. For each genetic variant, genotype information was compared using Akaike's information criteria to choose the best fit genetic model (dominant or recessive). | No
Helfand199 2011 | Cases = 203; Controls = 611 NR | Tests for HWE were performed for each SNP separately among control subjects with the use of Fisher's Exact Test. The genotypes and frequencies of the 17 different risk alleles were determined for all cases and controls and found to be in HW equilibrium. | The genotype information was compared using Aikake's Information Criteria to choose the best fit genetic model (dominant or recessive). | Positive family Hx
Nam195 2009 | 3,004 men underwent 1 or more biopsies (and had sufficient leukocyte DNA available for SNP analysis): Cases = 1,389; Controls = 1,615 NR | Yes, HWE assessed among controls; 6 of 25 SNPs (rs983085, rs6983561, rs7214479, rs6501455, rs4242382, ETV1) were not in HWE (p <0.001) | The authors examined 25 SNPs; 15 were reported by Zheng, et al., 2008,^188^ from chromosomal regions 8q24 and 17q. They also examined 10 other SNPs previously shown to be associated with CaP, from KLK2, TNF, HOGG,9p22, and ETV1-rs2348763 and ETv1-rs13225697 genes and from locus of HPC1 on chromosome 1q24. Also included were 2 SNPs from ERG genes (TMPRSS2:ERG). Genotype groupings were tested based on additive, dominant, and recessive genetic models for each SNP and the one with the highest LRT was chosen as the best model. For SNPs examined by Zheng, et al., they used their genotype groupings. | SNP panels for independent assessment: no additional variables included; Model 1, 2, and 3: adjusted for age, family Hx of prostate cancer, ethnicity, presence of urinary voiding symptoms, PSA level, free: total PSA ratio, and DRE.
Penney197 2009 | Physicians Health Study: Cases = 1,347; Controls = 1,462 SPORE: Cases = 3,714 FHCRC King County Case-control: Cases = 1,308; Controls = 1,266 Yes (all 3 studies) | No SNPs violated HWE in controls for Physicians Health Study or FHCRC King County case-control | SNPs that had a minor allele frequency of >10% were analyzed under a codominant model, whereas the less common SNPs were analyzed assuming a dominant inheritance model. | NR
Salinas189 2009 | Cases = 1,457 genotyped of the 1,754 interviewed; Controls = 1,645 were interviewed; Included in panel: Caucasian cases =1308; Caucasian controls = 1,266 Yes | HWE for the 5 SNPs in Caucasian control was assessed using Fisher's Exact Test; pairwise linkage equilibrium (LD) between SNPs estimated based on r2 | For each SNP genotype, models adjusted for age were used to test dominant, recessive and additive (0,1, or 2 copies of associated allele) genetic models. | Model 1 (Cumulative risk of 5 SNPs): adjusted for age and family Hx; Model 2: adjusted for age only
Sun190 2008a | JHH study: Cases = NR; Controls = <4.0ng/ml; CGEMS and CAPS study = NR Case-only analysis: data not shown | NR | NR | Not applicable (current study is validation study)
Sun194 2008b | HPC families = 168; Non-HPC cases = 1,404; Controls = 560 Duplicated and water sampled = yes; otherwise blinding not reported | Yes, for each SNP, tested whether observed genotype distributions were consistent with HWE expected proportions, separately for HPC probands, non-HPC, and controls using exact test, Tests for pairwise LD among SNPs in control subjects, and estimates for D' and r2 obtained using Haploview software. To minimize impact of multiple testing, for each SNP, only the “best” mode of inheritance model, suggested by earlier studies, was evaluated. | Comparisons of frequencies of alleles and genotypes between HPC probands and non-HPC patients and between HPC probands and unaffected controls were performed. For each SNP, homogeneity of allele frequencies was tested using a X2 test, with 1 degree of freedom. Genotype frequency differences, assuming an additive, dominant, or recessive mode-of-inheritance model, was tested using unconditional logistic regression models. Risk genotypes were compared to reference genotypes for each SNP (e.g., SNP: rs10086908, position 128,081,119 = TC/TT (risk) vs. TT and ORs produced for comparison between groups). | Models 1 and 2: adjusted for age
Sun198 2011 | Cases = 2,899 NR | NR | NR | Family Hx
Wiklund201 2009 | Cases = 2,875 NR | Each of the SNPs in autosomal chromosomes was in HWE (P>=0.05). | NR | NR
Xu193 2009 | CAPS: Cases = 2,899; Controls = 1,722 PLCO: Cases = 1,172; Controls = 1,157 NR | HWE for each SNP among control subjects in each study using Fisher's Exact Test. | The association between the number of risk alleles and family Hx with CaP risk was tested using a logistic regression model. | Family Hx
Zheng192 2009 | Cases = 2,899; Controls = 1,722 NR | Yes; Each of the SNPs in the autosomal chromosomes was in HWE (p >0.05) among controls. Tests for HWE done for each SNP separately among cases and controls using Fisher's Exact Test. Pairwise disequilibrium (LD) was tested for SNPs within same chromosomal region in control subjects. | Allele frequency differences, between case patients and control patients were tested for each SNP using x2 test with 1 degree of freedom. | Independent association of prostate cancer risk with each of the SNPs: adjusted for other SNPs as well as age, geographic region, and family Hx. ROC for three models including one with age, family Hx and 11 SNPs.
Zheng188 2008 | Cases = 2,893; Controls = 1,781 NR | Yes, for each SNP separately (cases and controls) using Fishers' Exact test. Pairwise linkage disequilibrium tested for SNPs within each of the 5 chromosomal regions (controls). | For genotypes, a series of tests assuming an additive, dominant, or recessive genetic model were performed for each of the 5 SNPs with the use of unconditional logistic regression. Differences in allele frequencies between cases and control subjects were tested for each SNP with the use of chi-square test with 1 degree of freedom. | Family Hx, age, and geographic region.

Abbreviations: CaP = prostate cancer; CAPS = cancer of the prostate in Sweden; CGEMS = cancer genetic markers of susceptibility; DNA = deoxyribonucleic acid; DRE = digital rectal examination; ERG = ETS related gene; ETS = E-twenty six; ETV1 = ETS translocation variant 1; FHCRC = Fred Hutchinson cancer research center; HOGG = human 8-oxoguanine glycosylase; HPC = hereditary prostate cancer; HPC1 = hereditary prostate cancer 1; HW = Hardy Weinberg HWE = Hardy Weinberg equilibrium; Hx = history; JHH = Johns Hopkins hospital; KLK2 = kallikrein-2; LD = linkage disequilibrium; LRT = likelihood ratio test; NR = not reported; OR = odds ratio; PLCO = prostate lung cancer ovarian; PSA = prostate specific antigen; ROC = receiver operating characteristic; SNP = single nucleotide polymorphism; SPORE = specialized programs of research excellence; TMPRSS2 = transmembrane protease serine 2; TNF = tumor necrosis factor

Table 10 Characteristics of included studies: Analysis and results

Author Year | Analysis Method of constructing SNP panel Method of validating SNP panel | Analysis Missing data Measures used to evaluate SNP panel | Results Number of participants included in analysis Mean age (SD) (by group) 1st degree family Hx CaP | Risk Score AUC ΔAUC Other Measure Subgroup analysis of risk score, AUC, delta AUC or other measure
Aly200 2011 | 35 SNPs, log total PSA, log free to total PSA ratio, age at biopsy, family Hx of CaP Allelic ORs were calculated using logistic regression models. For each man a genetic risk score was created by summing the number of risk alleles at each of the 35 SNPs multiplied by the log of that SNPs OR. | NR OR, AUC | Cases = 2,135; Controls = 3,108 Cases = 66; Controls = 64 Yes Cases = 29%; Controls = 22% | When using the nongenetic model the AUC was 64.2%; By using the genetic model the AUC was significantly improved to 67.4% (p=0.014). NR NR NR
Beuten196 2009 | 116 SNPs initially considered NR | Imputed for random forest and GMDR method. OR used for cumulative effects of risk variants. Testing accuracy & cross validation consistencies used for “best multi-genic models”. | 2,452 samples genotyped Cases = 65.5 (8.5); Controls = 60.8 (8.8) NR | Non-Hispanic Caucasians # risk genotypes 0 ref, 1 OR 1.39 (1.0 to 1.9), 2 OR 1.56 (1.11 to 2.20), 3 OR 2.87 (1.64 to 5.02) trend OR 2.20 (1.44 to 3.38) Hispanic Caucasians 0 Ref, 1 OR 1.88 (1.17 to 3.02), 2 OR 4.58 (2.19 to 9.61), trend OR 4.29 (2.11 to 8.72) NR NR Best multigenic models. 13 significant non-Hispanic Caucasians rs1538989-rs2479827-rs17523880-rs2470164 testing accuracy 0.63 p0.001. 19 significant Hispanic. By ethnicity
Helfand191 2010 | CaP cumulative risk was analyzed. The determined best fit genetic model for each genetic variant was used to examine the cumulative relationship between the original 5 SNPs and CaP risk in the population.204 NR | NR ROCs constructed with and without adjustment for age, compared as a ROC contrast statement in SAS for the models including 5 vs. 9 genetic variants; CaP cumulative risk on best fit genetic model measured by OR | Cases = 687; Controls = 777 Cases = 69.8 years; Controls = 58 years. No SDs given. NR | Age to adjusted ORs (95% CIs): 5 SNPs along 8q24 +17q + 0 to 1 carried variants = 1.00 (Ref); + 2 carried variants = 1.74 (1.32 to 2.29);+ 3 carried variants = 2.00 (1.47 to 2.71);+ 4 to 5 carried variants = 3.19(1.85 to 5.50); age to adjusted OR (95% CI): 2p15, 10q11, 11q13 + Xp11 SNPs + 0 to 1 carried variants = 1.00 (ref); + 2 carrier variants = 1.46 (0.74 to 2.86); +3 carrier variants = 2.46 (1.29 to 4.66); + 4 carrier variants = 3.05 (1.60 to 5.79); + 5 carrier variants = 4.39 (2.24 to 8.61); + 6 or more carrier variants = 5.75 (2.50 to 13.24) Model including all 9 variants = 0.61; model including 5 variants = 0.58 After adjustment for age, 9 variant model AUC = 0.66, and 5 variant model = 0.65 NR NR
Helfand199 2011 | NR NR | NR AUC | Cases = 203 Controls = 611 Cases = 58 Controls = 58 Yes Cases = 36% Controls = 15% | When the presence of family Hx was included in the analysis, we found that carriers of >10 genetic risk factors had an 11.2 fold increased risk of having CaP (p<0.0001) compared with men who were carriers of ≤5 risk alleles. AUC for the model including all the carrier numbers of all 17 risk variants was 0.655 [p<0.000, OR 1.4 (1.3-1.6)] When family Hx was included AUC=0.706, p,0.001 NR NR
Nam195 2009 | A panel of 15 initially considered SNPs and independent comparisons of allele frequencies in cases/controls were examined. Based on those associated with CaP from Zheng, et al., 2008.^188^ A second panel of SNPs for independent assessment was based on the authors' previous findings (Nam, et al., 2008;224 Nam, et al., 2005;225 Nam, et al., 2006^226^). Model 1 was based on 5 SNPs defined by Zheng, et al. Model 2 used a similar approach to Zheng, but the authors chose 4 SNPs with the most significant p-values from a panel based on their previous work. Model 3 used the two most significant SNPs selected from Zheng and two from Nam. NR | NR Independent association of prostate cancer risk with each of SNPs measured by OR and 95% CI; Cumulative effects of selected SNPs as seen in combination SNP Models 1, 2, and 3 measured using OR and 95% CI for prostate cancer using univariate and multivariate analyses; ROC constructed to estimate AUC of the various SNP models | Cases = 1,389; Controls = 1,615 At time of biopsy, mean age is prostate biopsies = 64.5 (range = 40 to 94 years); controls = NR (range ≤50 to ≥70 years Cases = 16.4%; Controls = 12.1%; obtained by research personnel through questionnaire and medical record review | Panel of SNPs (validation of Zheng, et al.): OR (95% CI) in order of SNPs as previously listed: rs4430796 = 1.04 (0.9 to 1.2), rs7501939 = 1.04 (0.8 to 1.3), rs3760511 = 1.02 (0.8 to 1.3), rs1859962 = 1.34 (1.1 to 1.6), rs16901979 = 1.07 (0.9 to 1.3), rs6983267 = 1.20 (1.0 to 1.4), rs7000448 = 1.16 (1.0 to 1.4), rs1447295 = 1.61 (1.3 to 1.9), rs7017300 = 1.50 (1.3 to 1.8), rs7837688 = 1.51 (1.2 to 1.8); Second Panel of SNPs from previous work. ERG rs2836431 = 1.36 (1.1 to 1.7), ERG rs8131855 = 1.34 (1.1 to 1.6), HOGG1 = 326 rs1052133 = 1.67 (1.2 to 2.3), KLK2 rs198972 = 1.16 (1.0 to 1.3), KLK2 rs2664155 = 1.24 (1.1 to 1.4), TNF rs1800629 = 1.27 (1.1 to 1.5), rs1552895 (9p22) = 1.21 (1.0 to 1.4), HPC1 (1q25,rs1930293) = 1.27 (1.1 to 1.5), ETV1 (7q21,rs2348763) = 1.25 (1.1 to 1.4); Combination models (0 associated genotypes (gt) = ref): model 1: 1 gt = 1.40 (1.1 to 1.7), 2 gt = 1.47 (1.2 to 1.9), 3 gt = 1.58 (1.1 to 2.2), ≤4 gt = 1.55 (0.9 to 2.8); model 2: 1 gt = 1.32 (0.9 to 1.9), 2 gt = 1.44 (1.0 to 2.0), 3 gt = 1.69 (1.2 to 2.4), ≥4 gt = 2.17 (1.3 to 3.6); model 3: 1 gt = 1.23 (1.0 to 1.5), 2 gt = 1.45 (1.1 to 1.8), 3 gt = 2.22 (1.5 to 3.2), ≥4 gt = 5.09 (1.6 to 16.5); From multivariate ROC analysis: AUC for baseline model including age, family Hx, ethnicity, presence of urinary voiding symptoms, PSA level, free: total PSA ratio, DRE = 0.72 (95% CI, 0.70 to 0.74). Adding SNPs from Zheng, et al. (model 1) to multivariate model, AUC = 0.73 (0.71 to 0.75). AUC from model 2 was 0.73 (0.71 to 0.74). AUC from model 3 was 0.74 (0.72 to 0.76, p = 0.0001). AUC of predictive model: Removing SNP genotype combination and compared it with incremental drops of variables: SNP combination from model 3 = drop of 0.014); age = 0.022; family Hx = 0.003; symptom score = 0.001; PSA = 0.001; Free: total PSA ratio = 0.066; DRE = 0.010 Positive predictive value (%) of PSA test based on established cut-off level of 4.0 ng/ml using genotype combination from model 3: 1 gt combinations = PPV Combination models (Caucasians only, OR, 95% CI): Model 1: 1 gt = 1.41 (1.2 to 1.7), 2 gt = 1.53 (1.2 to 1.9), 3 gt = 1.33 (0.9 to 2.0), ≥4 gt = 4.46 (1.4 to 13.9); Model 2: 1 gt = 1.22 (0.9 to 1.7), 2 gt = 1.49 (1.1 to 2.1), 3 gt = 1.76 (1.2 to 2.5), ≥4 gt = 2.38 (1.4 to 4.0); Model 3: 1 gt = 1.26 (1.0 to 1.6), 2 gt = 1.61 (1.3 to 2.1), 3 gt = 3.05 (2.0 to 4.6), ≥4 gt = 3.81 (1.2 to 12.3)
Penney197 2009 | CaP incidence was investigated only in PHS and FHCRC, as there are no controls in GELB. NR | NR Data analyzed by unconditional logistic regression, adjusting for matching factors to estimate OR; OR combined into summary estimate across PHS and FHCRC using random effects model with cohort as random effect | PHS: Cases = 1,347; Controls = 1,462 GELB: Cases = 3,714 (not in CaP incidence) FHCRC: Cases = 1,308; Controls = 1,266 PHS: 70.5 (7.7) GELB: 62 (8.2) FHCRC: 59.9 (7.0) NR in any study | Combined in PHS and FHCRC: rs13254738 AA = OR 1.00, AC OR = 1.03 (0.92 to 1.16), CC OR 1.28 (1.06 to 1.54); rs6983561 AA OR 1.00, AC/CC OR 1.54 (1.13,2.08); rs5693267 TT 1.00, GT OR 1.22(1.04 to 1.44), GG 1.41 (1.20 to 1.64), rs7000448 CC 1.00, CT 1.04 (0.93 to 1.17), TT 0.92 (0.78 to 1.09), rs1447295 CC 1.00, CA/AA 1.40 (1.23, 1.61), rs4430796 GG 1.00, AG 1.31 (1.11 to 1.54), AA 1.60 (1.37 to 1.88), rs1859962 TT 1.00, GT 1.18 (0.90,1.54), 1.48 (1.27, 1.73) in PHS only rs7008482 TT 1.00, GT 0.91 (0.77,1.07), GG 0.87 (0.68,1.12) NR NR Comparison of CaP mortality (death vs. 10 year survival); Gleason score; Pathologic Stage; Age and PSA at Dx
Salinas189 2009 | The best fitting models for each SNP (using Zheng, et al., 2008^188^) was selected based on the model with the greatest LRT. Confounding was evaluated by considering whether inclusion of other covariates changed the risk estimates ≤10%. P-values were derived from LRT statistics obtained by comparison of nested models. Goodness of fit was evaluated using the Hosmer-Lemeshow Test. Gene-gene and gene-environment interaction was evaluated using the LRT test comparing the full model with the main effect and an interaction term. PAR% was calculated for each SNP based on the OR obtained from the multivariate models. Corrected PAR% was calculated by solving a quadratic equation in which the absolute risk is a function of the observed OR, exposure prevalence in controls, and background disease. NR | Men with missing genotype information for any SNP excluded from independent SNP analyses Models 1 and 2: OR and 95% CI; comparison of models (subset analysis): AUC; ROCs (shown in figure, not presented in report); prostate cancer-specific mortality associated with each of the SNPs = hazard ratios and 95% CI (data not within scope of current review) | Main analyses (study I and II participants): Cases = 1,308 Controls = 1,266 Subset AUC analysis from Study I only: Cases = 475 Controls = 364 At Dx: Cases = 59.9 Controls = 59.6 Cases = 21.6% Controls = 11.1%; (time of Dx) obtained by trained male interviewers using standardized questionnaire | Model 1 = cumulative effect of associated genotypes at 5 SNPs: 1st degree family Hx of CaP = 2.31 (1.84 to 2.91), (0 associated genotype (gt) = reference, 1 gt = 1.48 (1.09 to 2.01), 2 gt = 1.88 (1.38 to 2.56), 3 gt = 2.97 (2.08), ≥4 gt = 3.36 (1.90 to 6.08); Model 2: cumulative effect of genotypes at 5 SNPs and family Hx: 0 gt (reference), 1 gt = 1.41 (1.02 to 1.97), 2 gt = 2.25 (1.63 to 3.13), 3 gt = 3.43 (2.40 to 4.94), 4 gt = 3.65 (2.24 to 6.03), ≤5 gt = 4.92 (1.58 to 18.53); Independent SNP Effects Models (study I and II participants): family Hx = 2.32 (1.85 to 2.92), Region 7q12: rs4430796 = 1.43 (1.19 to 1.71), Region 17q24.3: rs1859962 = 1.25 (1.03 to 1.51), Region 8q24: rs6983561 = 1.76 (1.30 to 1.64), rs6983267 = 1.34 (1.10 to 1.64), rs1447295 = 1.34 (1.10 to 1.63) Model with age at reference date, serum PSA (at Dx for cases, interviews for controls), and 1st degree relatives with CaP = 0.63 compared to same model with 5 SNPs added = 0.66. This was based on random subset of Study I participants only (cases = 475/controls = 364). Difference between the curves = 0.03 (95% CI, -0.12 to +0.06) PAR(%) for SNPs in the 8q24, 17q12, and 17q24.3 chromosomal regions: 1st degree family Hx of CaP = 11.8%, rs4430796 (AA gt) = 9.4%, rs1859962 (GG gt) = 5.3%, rs6983561 (CC+CA gts) = 4.5%, rs6983267 (GG+GT gts) = 19.8%, rs1447295 (AA+AC gts) = 6.0%, all 5 at risk SNPs (as above) = 38.1%, all 5 SNPs & family Hx = 54.4% Subset analysis of Study I participants only, as reported under AUC scores
Sun190 2008a | Multivariate analyses were done where all 5 SNPs, family Hx (excluding JHH), and age were included. Cumulative effects of the 5 SNPs were analyzed using the JHH study population and CGEMS study population (confirmation studies) using logistic regression. A subanalysis of the cumulative effect included family Hx because it was independent from the cumulative risk genotype effect. Cumulative effect of the 5 SNPs and family Hx on CaP in the CGEMS-prostate sample was estimated and compared to the CAPS sample and then combined, but not for the JHH sample, due to incomplete family Hx data. The combined analysis of 5 SNPs and family Hx was assessed by counting the number of prostate cancer associated genotypes (based on best fit genetic model from Zheng, et al., and coded as ‘1’ if the individual carried the risk factors and ‘0’ otherwise for each of the 6 factors in each subject. This model is validating the previously reported model from Zheng, et al., 2008^188^ | One SNP (rs16901979) imputed from the adjacent genotyped SNPs at 8q24 using IMPUTE software; computed confidence scores to ensure reliable imputation Cumulative effect of 5 SNPs in three independent studies: OR for prostate cancer for men carrying any combination of 1,2,3, or ≥4 risk genotypes estimated by comparing to men carrying none of the risk genotypes using logistic regression | Combined cumulative analysis (all three study populations): Cases = 5,628 Controls = 3,514 NR JHH study - ‘not complete’; CAPS and CGEMS studies - yes | Cumulative Combined Effect of 5 SNPs Model 1 from Combining data from Johns Hopkins Study + CGEMS-prostate study + CAPS study : ORs (95% CI) all compared to reference 0 SNPs: = 1 SNP: 1.41 (1.20 to 1.67), 2 SNP: 1.88 (1.59 to 2.22), 3 SNPs: 2.36 (1.95 to 2.85), and ≥4 SNPs: 3.80 (2.77 to 5.22); Cumulative Combined Effect of 6 Risk Variants (5 SNPs + family Hx) Model 2 from the CAPS and CGEMS studies = 1 SNP: 1.64 (1.34 to 2.00), 2 SNPs: 2.07 (1.70 to 2.51), 3 SNPs: 2.82 (2.28 to 3.50), 4 SNPs: 4.61 (3.40 to 6.25), ≥5 SNPs: 11.26 (4.74 to 24.75). Case-only analysis: no statistically significant association was found between 5 SNPs and Gleason score, age at Dx, presence of family Hx, (CGEMS only), or aggressiveness of prostate cancer NR Trend test was statistically significant in the CGEMS-prostate (p = 4.75 × 10 to 14) and in the combined CAPS and CGEMS-prostate (p = 1.94 × 10 to 39). NR
Sun194 2008b | 12 SNPs were selected based on the published literatureTo minimize the impact of multiple testing for each SNP, only the best mode-of-inheritance model, was evaluated. OR and 95% CI was estimated for men with previously identified risk genotypes, compared to men without, under these genetic models. Family-based association tests were performed utilizing data from nuclear families, sibships, or a combination of the two to test for linkage and linkage disequilibrium between traits and genotypes. An empirical variance estimator in FBAT was used to perform a valid test of association, accounting for the correlation of alleles among multiple affected individuals in the same family due to linkage. The LAMP computer program was used to jointly model linkage and association in the 168 families with HPC, and to calculate the LRT of marker data conditional on trait data under several models. LAMP uses a LRT to test for linkage and/or linkage disequilibrium. NR | NR Estimated genotype risk (Models 1) of 8q24: OR and 95% CI; Cumulative effects of 8q24 risk variants (Models 2): OR and 95% CI (and p-values) | Estimated Genotype Risk (models 1): HPC = 221 Controls = 560; Non-HPC Cases = 1,404 Controls = 560 Cumulative effect of 8q24 (models 2) = HPC vs. controls; Non-HPC vs. controls: 0 risk genotypes: HPC probands = 96; Non-HPC cases = 678; Controls = 560; 1 risk genotypes: HPC = 97; Non-HPC = 559; Controls = 192; ≥2 risk genotypes: HPC = 28; Non-HPC cases = 167; Controls = 36; Described previously (Xu, et al., 2001)223 221 HPC cases (at least 2 additional 1st degree relatives diagnosed with prostate cancer) verified by medical records | Model 1 (genotype risk vs. ref) OR (95%CI) (HPC vs. Controls): Region 1 = rs1447295: 2.25 (1.52 to 3.32), rs4242382: 2.37 (1.61 to 3.50), rs7017300: 1.86 (1.29 to 2.67), rs10090154: 2.33 (1.57 to 3.45), rs7837688: 2.51 (1.71 to 3.70); Region 2 = rs10086908: 0.88 (0.63 to 1.22), rs13254738: 0.99 (0.68 to 1.32), rs6983561:1.76 (1.05 to 2.94), rs16901979: 1.70 (1.02 to 2.84); Region 3 = rs6983267: 1.29 (0.89 to 1.86) , rs7000448: 0.54 (0.30 to 0.96), Region c to MYC = rs6470572 : 1.09 (0.78 to 1.52); (Non to HPC vs. controls): Region 1 = rs1447295: 1.73 (1.33 to 2.26), rs4242382: 1.81 (1.38 to 2.34), rs7017300: 1.44 (1.14 to 1.82), rs10090154: 1.74 (1.33 to 2.27), rs7837688: 1.80 (1.38 to 2.36); Region 2: rs10086908: 0.92 (0.76 to 1.12), rs13254738: 1.00 (0.82 to 1.22), rs6983561:1.14 (0.80 to 1.62), rs16901979: 1.13 (0.79 to 1.60); Region 3 = rs6983267: 1.42 (1.14 to 1.78) , rs7000448:1.26 (0.95 to 1.67); Region c to MYC = rs6470572 : 0.91 (0.74 to 1.12); Model 2 (Cumulative Effect) OR (95% CI): HPC vs. Controls: 0 risk genotypes = ref., 1 risk genotype = 1.76 (1.24 to 2.49), ≥2 risk genotypes = 2.94 (1.67 to 5.15), Non to HPC vs. Controls: 1 genotype = 1.42 (1.15 to 1.75), = >2 genotypes = 2.23 (1.52 to 3.28) NR NR NR NR
Sun198 2011 | Family Hx, 5 SNPs, 11 SNPs, 28 SNPs sequentially discovered from GWAs in the 4 years preceding December 2009 Multiplicative model; Estimated sensitivity and specificity, PPV, and NPV, and used AUC statistic | NR AUC | Cases = 2,899; Controls = 1,722 Cases = 66; Controls = 67 Yes Cases = 19%; Controls = 9% | AUC was 0.60 for 5 SNPs, 0.61 for 11 SNPs and 0.62 for 28 SNPs NR NR NR
Wiklund201 2011 | 16 SNPs selected from 4 GWAs NR | NR Survival Analysis, Cox regression methods | Cases = 2,875 Age = 35 – 79 NR | NR NR NR NR
Xu193 2009 | The association of a number of risk alleles and family Hx with CaP risk was tested using a logistic regression model adjusted for age and geographic region (CAPS). NR | NR Absolute risk estimated based on OR, calibrated incidence rate of CaP for men with most common number of risk alleles, negative family Hx, and mortality rate for all causes excluding CaP in Sweden and the U.S. | CaPs: Cases = 2,899; Controls = 1,722 PLCO screening trial: Cases = 1,172; Controls = 1,157 NR 1^st^ and 2^nd^ degree relative +ve CaPs: Cases = 550/2,898; Controls = 163/1,721 PLCO: Cases = 1,36/1,176; Controls = 67/1,101 | OR (95%CI) [underlined: CaPs with no family Hx] 0 to 7 risk alleles 0,71 (0.55 to 0.91), 8 risk alleles 0.78 (0.61 to 1.01), 9 r.a. 0.95 (0.76 to 1.21), 10 r.a. 0.99 (0.80 to 1.24), 11 r.a. 1.00 (baseline), 12 r.a.1.13 (0.91 to 1.41), 13 r.a. 1.41 (1.10 to 1.79), ≥14 2.26 (1.79 to 2.86) [underlined: CaPs with family Hx] 0 to 7 risk alleles 1.54 (1.12 to 2.12), 8 r.a.1.70 (1.24 to 2.33), 9 r.a. 2.07 (1.54 to 2.80), 10 r.a. 2.16 (1.61 to 2.89), 11 r.a., 2.17 (1.80 to 2.63),12 r.a. 2.45 (1.84 to 3.27), 13 r.a. 3.06 (2.25 to 4.15), ≥14 4.92 (3.64 to 6.64) NR NR NR NR
Zheng192 2009 | The panel consisted of the independent association of prostate cancer risk with each SNP (significantly associated from an allelic test). The model with the highest LRT was considered as the best-fitting genetic model for the respective SNP. Backward selection was used for independent association with each of the significantly associated SNPs (adjusting for age, geographic location and family Hx). To assess the utility of these SNPs and family Hx in predicting men with and without CaP, sensitivity and specificity for predicting CaP was estimated using various cutoffs of number of alleles and family Hx. AUC statistics were estimated for several predictive models after fitting a logistic regression, including model 3 = age, family Hx, and genetic variants. CaP risk and 19 SNPs identified from previous GWA studies imply its validation of previously reported significantly associated SNPs. No validation within the study was reported for ROCs and AUC statistics. | Missing data treated as missing values in the analyses Independent association of prostate cancer risk with each of SNPs measured by OR and 95% CI; Overall predictive performance of predictive models | Cases = 2,899; Controls = 1,722 At enrolment: Aggressive cases = 68.04 (7.32); Nonaggressive cases = 65.14 (6.74) All cases = 66.36 (7.13); Controls = 67.15 (7.39) [No family Hx: Aggressive cases = 82.29%; Nonaggressive cases = 79.99% All controls = 90.57%] Overall: Cases = 19.1%; Controls = 14% (same as Zheng, et al.) | Independent Association with each SNP: ORs (95% CI) = family Hx only = 2.19 (1.80 to 2.67); age only = 1.02 (1.00 to 1.03); geographic region = 0.46 (0.38 to 0.54); rs2660753 = 1.32 (1.12 to 1.55); rs9364554 = 1.08 (0.98 to 1.19); rs10486567 = 1.39 (1.04 to 1.85); rs6465657 = 1.14 (1.04 to 1.25); rs16901979 = 1.65 (1.32 to 2.08); rs6983267 = 1.22 (1.12 to 1.34); rs1447295 = 1.16 (1.01 to 1.34); rs1571801 = 1.15 (1.04 to 1.27); rs10993994A = 1.16 (1.06 to 1.27); rs10896449B = 1.12 (1.02 to 1.22); rs4430796 = 1.22 (1.11 to 1.33); rs1859962 = 1.17 (1.07 to 1.28); rs5945619C = 1.19 (1.05 to 1.36). No interactions were statistically significant (p >0.05) (data not shown). Predictive Models: model 1 (age) = 0.58 (0.56 to 0.59), model 2 (age and family Hx) = 0.61 (0.59 to 0.62), model 3 (age, family Hx, 11 SNPs = 0.65 (0.63 to 0.66), model 4 (age, family Hx, geographic region & 5 previously evaluated SNPs (Zheng 2008) = 0.63 (0.62 to 0.65) Difference AUC mode 2 to model 1 = 0.03 ; difference between model 3 and 2 = 0.04; Difference in AUC statistically significant between models 2 and 1 for additional effect of family Hx: p = 1.36 × 10 to 7, and between models 3 and 2: p = 2.3 × 10 to 10. Among 23 risk factors (22 risk alleles from 11 SNPs and family Hx), cutoff of 11 risk factors = sensitivity and specificity (0.25 and 0.86, respectively) which were similar to PSA level cutoff of 4.1ng/ml. Sensitivity and specificity of the genetic factors to predict specific types of this cancer: No differences were found for any specific types of prostate cancer
Zheng188 2008 | The likelihood ratio test (LRT) for the best fitting genetic model of individual SNPs, adjusting for age and geographic region were given. The independent effect of the 5 regions were given by including the most significant SNP from each of the 5 regions in a logistic regression model using backwards selection. Multiplicative interactions were tested for each pair of SNPs by including both main effects and an interaction term using logistic regression. Cumulative effect of the 5 SNPs was tested by counting the number of genotypes associated with prostate cancer (from single SNP analysis) for the 5 SNPs in each subject. Subanalysis included cumulative effect, including 5 SNPs and family Hx. NR | NR OR, AUC, PAR for each model | Aggressive disease cases = 1,231; Localized disease cases = 1,619; Controls = 1,781 Cases = 66.4 (7.1); Controls = 67.2 (7.2) Cases = 19.0%; Controls = 9.4% | OR (95% CI): Age + 0 SNPs = 1.01 (1.00 to 1.02); Geographic region + 0 SNPs = 0.47 (0.40 to 0.55); 1 SNp = 1.62(1.27 to 2.08); 2 SNPs = 2.07 (1.62 to 2.64); 3 SNPs = 2.71 (2.08 to 3.53); 4 SNPs = 4.76 (3.31 to 6.84); ≥5 SNPs = 9.46 (3.62 to 24.72) 63.3 (95% 61.7 to 65.0) for model 3 (age, region, family Hx, and # genotypes associated with CaP at the 5 SNPs) NR NR NR

Abbreviations: AUC = area under the curve; ΔAUC = change in the area under the curve; CaP = prostate cancer; CAPS = cancer of the prostate in Sweden; CGEMS = cancer genetic markers of susceptibility; DNA = deoxyribonucleic acid; DRE = digital rectal examination; Dx = diagnosis; ERG = ETS related gene; ETS = E-twenty six; ETV1 = ETS translocation variant 1; FBAT-family based association test; FHCRC = Fred Hutchinson cancer research center; GMDR = generalized multifactor dimensionality reduction; HOGG = human 8-oxoguanine glycosylase; HPC = hereditary prostate cancer; HPC1 = hereditary prostate cancer 1; HW = Hardy Weinberg HWE = Hardy Weinberg equilibrium; Hx = history; JHH = Johns Hopkins hospital; KLK2 = kallikrein-2; LAMP = linkage and association modeling for pedigrees; LD = linkage disequilibrium; LRT = likelihood ratio test; NR = not reported; OR = odds ratio; PAR = population attributable risk; PHS = physicians' health study; PLCO = prostate lung cancer ovarian; PPV = positive predictive value; PSA = prostate specific antigen; ROC = receiver operating characteristic; SAS = statistical analysis software; SD = standard deviation SNp = single nucleotide polymorphism; TNF = tumor necrosis factor

There was complete overlap in the participants included from five of the six studies that included Sweden: a risk model was initially developed for a panel of 5 SNPs,188 extended to 11 SNPs192 in data from the same participants, then 14 SNPs,193 and then 28 SNPs;198 the study of prostate cancer survival used a 16-SNP panel.201 For the initial 5-SNP model, validation was undertaken in King County (Washington, United States),189 and a combined estimate of the cumulative effect of the five risk variants was made, which incorporated these data and the Swedish data.190 For the 14-SNP model, data from the United States were used for confirmation;193 the U.S. data in this study was based on the same participants (in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Trial)90 as in one of the U.S. studies used to validate the 5-SNP model.190 There was also overlap between the studies in the United States, first of participants recruited at the Johns Hopkins Hospital, Baltimore 1999-2006,^190,194^ second in participants recruited in King County, Washington 1993-2002 to 2002-2005,^189,197^ and third in participants recruited in Chicago 2002-2008^191^ and 1997-2009.^199^

Nine of the studies were concerned solely with the development of models for the prediction of risk for prostate cancer,188,192,194,196-201 two solely with model validation,189,190 and three with both development of new models and validation of previously-developed models.191,193,195 All five of the studies that carried out model validation used data independent of those in which the models had been developed. However, in two of the studies, the teams of investigators validating the models included some who were also involved in the model development.190,193

Most of the studies related to participants of European origin. In all but one200 of the studies of Swedish participants,188,190,192,193,198,201 the ethnicity was not explicitly specified. All but one of the studies of United States' participants were limited to men of European origin.189-191,193,194,197,199 The exception to this presented a stratified analysis for non-Hispanic European (54 percent of controls), Hispanic (33 percent), and African-American origin (13 percent).196 The study including Canadian subjects also related to ethnically diverse participants: European origin (81 percent of controls), Asian (8 percent), black (7 percent), and other (4 percent); some analyses were adjusted for ethnicity and some were restricted to participants of European origin.195

In one study, estimates were presented separately for cases from families in which two additional first-degree relatives had been diagnosed with prostate cancer and for cases that were recruited irrespective of family history.194

Eight studies presented information on the proportion of cases and controls with a family history of prostate cancer. In five, this was specified as relating to first-degree relatives – in three different analyses of the same Swedish participants, the proportion of cases with a family history was 19 percent and controls 9.4 percent,188,192,198 in a study in King County, WA, the proportions were 21.6 percent and 11.1 percent, respectively,189 and in the study in which cases were recruited in Chicago, IL, and St. Louis, MO, the proportions were 36.4 percent and 14.9 percent.199 In one study, family history referred to first- and second-degree relatives, and the proportion of cases for which such a history was reported was 11.6 percent and of controls 6.1 percent.193 In the other two studies, the degree of relationships included in “family history” were not defined: in the Canadian study, the proportion for cases was 16.4 percent and for controls was 12.1 percent,195 while in the Stockholm study, the proportions were 29.0 percent and 21.9 percent respectively.200

Ten articles were based on newly incident cases, one that related to the Canadian study (cases detected following referral for prostate-specific antigen (PSA) ≥4.0ng/mL or abnormal digital rectal examination without previous history of prostate cancer),195 six to data on the same participants from Sweden,188,190,192,193,198,201 one to the Stockholm study,200 and two to partially overlapping studies from the United States.189,197

Two publications (one of which also reported on participants from Sweden) reported analyses on prevalent cases from overlapping studies in the United States.190,194 One study in the United States was based on a mixture of newly incident and prevalent cases.196 In another two, it was unclear whether the cases were newly incident or prevalent – it was stated only that the cases were recruited after radical prostatectomy.191,199

The mean age of cases ranged from 56.8 years193 to 70.5 years.197 There was no obvious pattern according to inclusion of newly incident or prevalent cases.

As might be expected given trends in PSA testing, there appeared to be a pattern that the average PSA level at diagnosis of cases was lower for more recent study periods. The proportion of cases with a PSA level of ≤4ng/ml varied between under 8 percent in Canada 1999-2007^195^ and Sweden 2001-2003,^188,192,198^ to 13.6 percent in Washington State (United States) 1993-1996 and 2002-2005,^202^ and 22 percent in Chicago 2002-2008.^191^

Where reported (n=9), the proportion of cases with a Gleason score of ≤6 at diagnosis ranged from 51 percent (Physicians' Health Study) 1982-2008^197^ to 81 percent (Chicago and St. Louis 1997-2009).199 Only one study190 explicitly referred to having used the revised scoring as described by Epstein, et al.,62 for the Johns Hopkins Hospital component of the study. The stage at diagnosis was reported for the Swedish cases,188,192,198,200,201 in the study comprising three sets of cases and controls in the United States,197 and the Chicago study;191 over two-thirds of the cases were stage T2 or less at diagnosis. All of the cases in the Chicago-St. Louis study were stage T1c at diagnosis.199

In some of the studies, cases and controls clearly derived from the same study base. Thus, in the Canadian study, controls were selected from the same group of men referred to the prostate cancer centers of the University of Toronto who had either a PSA value ≥4.0ng/ml or an abnormal digital rectal examination (DRE), and who had no biopsy evidence of prostate cancer.195 In five of the studies including Swedish cases, the controls were population-based and selected from the Swedish population registry.188,190,192,193,198 In the Stockholm study, participants had undergone at least one prostate biopsy.200 The cases from the PLCO Trial were compared with controls participating in the trial.193,203 Cases arising in the Physicians' Health Study197 and cases from the San Antonio cohort196 were compared with controls selected from the same cohorts. Cases with prostate cancer in King County, Washington were compared with men without a self-reported history of prostate cancer who were resident in the county and identified by random digit dialing (participation rate 44.5 to 51.6 percent).189,197 Cases from the Johns Hopkins Hospital series, all of whom had undergone radical prostatectomy, were compared with men undergoing surgery for prostate cancer at the Johns Hopkins Hospital and in the greater Baltimore metropolitan area who had normal DRE, PSA <4.0ng/ml, and were aged >55 years.190,194 Cases for the Northwestern Memorial Hospital series, all of whom had undergone radical prostatectomy, were compared with 777 healthy male volunteer controls; from these, 247 may have been selected for the Icelandic genealogical database or from other genome-wide association (GWA) studies at deCODE, while the remaining participants were from a prostate cancer screening program done in April 2007 (it is not stated where this occurred).191,204 In the Chicago-St. Louis study,199 203 stage T1c cases (who had undergone radical prostatectomy, had a PSA <4.0ng/ml and a nonsuspicious DRE) were compared with 611 controls who had a PSA <4.0ng/ml, normal DRE, and no prior history of prostate biopsy that are stated to have been selected from a GWA study that included participants from the University of Chicago and Northwestern,205 per an email from W. Catalona. M.D.( WCatalona@nmff.org) on February 2, 2012.

## Source of Funding and Conflict of Interest

All of the studies were publicly funded. In addition, two studies received support from deCODE Genetics.191,199 All but five studies189,190,194,198,199 included conflict of interest statements. Of the nine studies in which there was such a statement, two referred to the filing of a patent application188,192 and two indicated specific nonpublic funding received by one of the authors.191,197

## Overview of the SNP-Based Genotype Panels

There were 15 panels identified from the included studies (Tables 11 and 12). The number of SNPs included in the panels ranged from two to 35. Almost all of the individual SNPs had been discovered and replicated as being associated with prostate cancer in GWA studies.

Table 11 Focus 5 test

5-SNP Panel (Focus 5)
Chromosome | rs Number | Replicated in GWA Studies | Zheng188 | Salinas189 | Sun190 | Nam195 model 1 | Helfand191 | Zheng192
8q24 (region 1) | rs1447295 | Yes | x | x | x | x | x | x
8q24(region2) | rs16901979 | Yes | x | x^a^ | x (imputed in PLCO) | x | x^b^ | x
8q24(region3) | rs6983267 | Yes | x | x | x | x | x^b^ | x
17q12 | rs4430796 | Yes | x | x | x | x | x^c^ | x
17q24 | rs1859962 | yes | x | x^c^ | x | x | x | x
Variables adjusted for | | | Age, geographic region and family Hx | Age (and serum PSA, family Hx in AUC analysis) | | None and age, family Hx, ethnicity, urinary symptoms, PSA, free: total PSA ratio and DRE | Age | In AUC analysis, age and family Hx
Variables added to model containing SNPs | | | Family Hx | Family Hx | Family Hx

a substituted by rs6983561, with which it was perfectly correlated

b additive model, in contrast to other five studies in which 5-SNP panel assessed

c dominant model, in contrast to other five studies in which 5-SNP panel assessed

Abbreviations: AUC = area under the curve; DRE = digital rectal exam; GWA = genome-wide association studies; Hx = history; PLCO = Prostate Lung Colon and Ovarian Cancer Screening Trial; PSA = prostate specific antigen; SNP = single nucleotide polymorphism

Table 12 Summary of SNPs and other variables included in test panels

SNP | | | 9-SNP Panel191 | 17-SNP Panel199 | 11-SNP Panel192 | 14-SNP Panel | 16-SNP Panel | 28-SNP Panel | 3 SNPs in 8q24 | 4-SNP Test | 4-SNP Test | 3-SNP Test | 2-SNP Test | 6-SNP Panel | 35-SNP Panel
Chromosome | rs number | Replicated in GWA studies^§^ | Helfand191 | Helfand199 | Zheng192 | Xu193 | Wiklund201 | Sun198 | Sun194 | Nam195 model 2 | Nam195 model 3 | Beuten196 | Beuten196 | Penney197 | Aly200
1q25 | rs1930293 | | | | | | | | | x
2p15 | rs2710646 | | x
2p15 | rs721048 | yes | | x | (ass) | | x | x | | | | | | | x
2p21 | rs1465618 | | | | | | | x | | | | | | | x
2p21 THADA | rs1465618 | yes
2q31 | rs10207654
2q31.1 | rs12621278 | | | | | | | x | | | | | | | x
3 | rs10934853 | | | | | | | x
3p12 | rs2660753 | yes | | | x | x
3q21.3 | rs4857841 | | | | | | | | | | | | | | x
3q21.3 | rs10934853 | yes | | x
4q22 PDLIM5 | rs17021918
4q22.3 | rs12500426 | | | | | | | | | | | | | | x
4q22.3 | rs17021918 | | | | | | | x | | | | | | | x
4q24 | rs7679673 | yes
5p15 | Rs2736098 | | | x
5p15 | Rs401681 | | | x
6q25 | rs9364554 | yes | | | x
6q25.3 | rs9364554 | | | | | | x | x | | | | | | | x
7p15.2 | rs10486567 | | | | | | x | | | | | | | | x
7q21.3 | rs6465657 | | | | | | x | | | | | | | | x
7p15 | rs10486567 | yes | | | x | x
7q21 | rs6465657 | yes | | | x | x
7q21 | rs2348763 | | | | | | | | | x | x
8 | rs2928679 | | | | | | | x
8 | rs1512268 | | | | | | | x
8p21 | rs1512268 | yes
8p21.2 | rs1512268 | | | | | | | | | | | | | | x
8q24 | rs7008482 | | | | | | | | | | | | | x
8q24 | Rs16902094 | yes | | x | | | | x | | | | | | | x
8q24 (region 1) | rs1447295 | yes | x | x | x | x | x | | x | | x | | | x | x
8q24 (region 1) | rs4242382 | yes | | | | | | | (ass)
8q24 (region 1) | rs7017300 | | | | | | | | (ass) | x
8q24 (region 1) | rs10090154 | | | | | | | | (ass)
8q24 (region 1) | rs7837688 | yes | | | | | | | (ass) | x
8q24 (region 1) | rs6470572 | | | | | | | | (ass)
8q24 (region 2) | rs16901979 | yes | x | x | x | x (imputed in PLCO) | x | | x | | | | | | x
8q24 (region 2) | rs10086908 | | | | | | | | (ass) | | | | | | x
8q24 (region 2) | rs13254738 | | | | | | | | (ass) | | | | | x
8q24 (region 2) | rs6983561 | | | | | | | | | | | | | x | x
8q24 (region 3) | rs6983267 | yes | x | x | x | x | x | | x | x | | | | x
8q24 (region 3) | rs7000448 | | | | | | | | (ass) | x | | | | x
8q24.21 | rs12543663 | | | | | | | | | | | | | | x
8q24.21 | rs1016343 | | | | | | | | | | | | | | x
8q24.21 | rs13252298 | | | | | | | | | | | | | | x
8q24.21 | rs445114 | | | | | | | | | | | | | | x
8q24.21 | rs620861 | | | | | | | x | | | | | | | x
8q24.21 | rs6983267 | | | | | | | | | | | | | | x
8q24.21 | rs16902104
8q24.21 | rs445114 | yes | | x
9p22 | rs1552895 | | | | | | | | | x
9q33 | rs1571801 | | | | x
10q11 | rs10993994 | yes | x | x | x | x
10q11 | rs7920517 | | | | (ass)
10q11.23 | rs10993994 | | | | | | x | | | | | | | | x
10q26 | rs4962416 | yes | | | (ass)
10q26.13 | rs4962416 | | | | | | x | x | | | | | | | x
11p15.5 | rs7127900 | | | | | | | x | | | | | | | x
11q13 | rs7931342 | yes | | | (ass)
11q13 | rs10896450 | | x | x
11q13 | rs11228565 | | | x
11q13 (region1) | rs10896449 | yes | | | x
11q13 (region2) | rs12418451
11q13.2 | rs12418451 | | | | | | | x | | | | | | | x
11q13.2 | rs11228565 | | | | | | | | | | | | | | x
11q13.2 | rs10896449 | | | | | | x | | | | | | | | x
17q12 | Rs11649743 | | | x | | | | | | | | | | | x
17q12 | rs4430796 | yes | x | x | x^b^ | x | x | | | x | | | | x | x
17q12 | rs7501939 | yes | | | | | | | | x
17q12 | rs3760511 | | | | | | | | | x
17q24 | rs1859962 | yes | x | x | x^b^ | x | x | | | | x | | | x | x
19q13.2 | rs8102476 | yes | | x | | | | x | | | | | | | x
19q13 (KLK2/KLK3) | rs2735839 | yes | | | (ass) | | x | x | | | | | | | x
19q13 (KLK2/KLK3) | rs5759167 | yes
22q13 | | | | | | x
22q13.1 | rs9623117 | | | | | | | | | | | | | | x
22q13.2 | rs5759167 | | | | | | | x | | | | | | | x
ERG | rs2836431 | | | | | | | | | x
ERG | rs8131855 | | | | | | | | | x
CYP19 | rs12439137 | | | | | | | | | | | x (nHW)
CYP19 | rs2470152 | | | | | | | | | | | x (nHW)
CYP19 | rs10459592 | | | | | | | | | | | | x (HW)
CYP24A11 | rs3787554 | | | | | | | | | | | | x (HW)
HOGG1-326 | rs1052133 | | | | | | | | | x
HSD3B2 | rs1819698 | | | | | | | | | | | x (nHW)
KLK2 | rs198972 | | | | | | | | | x
KLK2 | rs2664155 | | | | | | | | | x
Region c-MYC | rs6470572 | | | | | | | | (ass)
TERT | rs401681 | With serum PSA levels
TNF | rs1800629 | | | | | | | | | x | x
Xp11.22 | rs5945619 | | | | | | x | | | | | | | | x
Xp11 | rs5945572 | yes | x | x | (ass)
Xp11 | rs5945619 | yes | | | x
11p15 | rs7127900 | yes
Variables adjusted for | | | Age | | In AUC analysis, age, and family Hx | | | | | | age, family Hx, ethnicity, US, PSA, free: total PSA ratio and DRE
Variables added to model containing SNPs | | | | | | Family Hx

§ based on information in Table 1

a substituted by rs6983561, with which it was perfectly correlated

b additive model, in contrast to other five studies in which 5-SNP panel assessed

c dominant model, in contrast to other five studies in which 5-SNP panel assessed

Abbreviations: AUC = area under the curve; ass = assessed in single SNP analysis, but not included in panel; DRE = digital rectal exam; HW = Hispanic whites; nHW = Non-Hispanic whites; Hx = history; PSA = prostate specific antigen; rs = Reference SNP; US=urinary symptoms

Apart from overlap for the five SNPs included in the Focus 5 test panel, there were considerable differences between the panels assessed (Table 12).

The first test panel included five SNPs as described in the article of Zheng, et al.,188 and is the basis of the Focus 5 predictive test for prostate cancer. A patent application has been filed by Xu, et al.,206 “Methods and compositions for correlating genetic markers with prostate cancer risk.” The test has been marketed by Proactive Genomics.207 Four other articles assessed this test in independent data.189-191,195

The second test, again initially proposed by Zheng, et al.,188 included family history with the five SNPs included in the first test, and two of the articles that assessed the first test panel also assessed this test.189,190 In two of these studies, family history was defined to include first degree relatives.188,189

The other 13 tests were reported in 11 articles191-201 (Table 11). Four of these included family history, two in first-degree relatives,192,198 one in first- and second-degree relatives,193 and one in relatives of unspecified degree.200

deCODE markets the deCODE ProstateCancer test, which tests for 27 genetic variants associated with prostate cancer in men of European descent (including the five SNPs included in the Focus 5 test), a subset of 9 variants for African-American men, and a subset of 12 variants for men of East Asian descent (Table 13); the specific variants in the subsets are not specified in the Web site (www.decodhealth.com/prostate-cancer).208 If the deCODE ProstateCancer is sought separately, it has to be obtained through a licensed health professional. The test can also be ordered as part of the deCODEme Complete Scan, which analyzes genetic risk factors for 47 traits and conditions ($1,100 USD as of 19 June 2011) or the deCODEme Cancer Scan, which analyzes genetic risk factors for seven types of cancer ($500 USD).209 A patent application was filed by Gudmundsson, et al., in May, 2010.^210^

Table 13 Genetic variants tested for by deCODE ProstateCancer

Chromosome | rs Number
8q24 (region 1) | rs1447295
8q24 (region2) | rs16901979
8q24 (region2) | rs10086908
8q24 (region3) | rs6983267
17q12 | rs4430796
17q24 | rs1859962
19q13.2 | rs8102476
19q13 (KLK2/KLK3) | rs2735839
19q13 (KLK2/KLK3) | rs5759167
2p15 | rs2710646
3p12 | rs2660753
6q25 | rs9364554
7p15 | rs10486567
7q21 | rs6465657
10q11 | rs10993994
11q13 (region1) | rs10896449
Xp11 | rs5945572
4q22 PDLIM5 | rs17021918
TERT | rs401681
11p15 | rs7127900
8p21 | rs1512268
4q24 | rs7679673
2q31 | rs10207654
3q21.3 | rs10934853
8q24.21 | rs16902104
2p21 THADA | rs1465618
8q24.21 | rs445114

## KQ1 What is the analytic validity of available SNP-based panels designed for prostate cancer risk assessment?

### 1 What is the accuracy of assay results for individual SNPs in current test panels?

No data addressing this question were identified in the literature search. Companies known to offer testing for the risk for prostate cancer based on SNP panels were approached in May 2011, as were companies known to offer genetic testing more generally. As of September 1, 2011, no response had been received. From the articles that were identified as providing information relevant to the assessment of the clinical validity of SNP panels (KQ2), no data were presented on the analytic validity of individual SNPs from which the panels were composed.

### 2 What is the analytic validity of current test platforms whose purpose is, or includes, predicting risk of prostate cancer?

5-SNP panel. The 5-SNP panel that is the basis of the Focus 5 test, and the test that incorporates family history of prostate cancer, was genotyped using the Mass ARRAY QGE iPLEX system (Sequenom) in the report in which these models were developed.188 The same method was applied in samples from the Johns Hopkins Hospital190 and Canada.195 Some of the analytic validity information relevant to the initial study in Swedish samples188 are reported in other articles which relate to the same platform, including the initial five SNPs as well as additional SNPs.192,193,201 A call rate of 98.3 percent was reported,192,193,201 with a concordance rate for duplicate SNPs of >99 percent, and the genotypes for each SNP conformed to Hardy-Weinberg equilibrium (HWE) in controls.188,192,193 (For the purpose of this report, call rate was defined as the proportion of samples for which genotypes are called for a converted marker). It was not reported whether genotyping was done blind to case-control status.

The 5-SNP panel was genotyped with one modification (substitution of rs6983561 for rs16901979; it was stated that there was perfect correlation between these two SNPs in HapMap CEPH individuals), in a study using the Applied Biosytems (ABI) SNPlex Genotyping System.189 There was perfect agreement for the five SNPs between 140 blind duplicate samples distributed across all genotyping batches. Genotyping was done blind to case-control status. All genotype frequencies observed in controls were consistent with HWE.

One of the sets of samples used to assess the 5-SNP panel was the PLCO trial.190 Four of the SNPs had already been genotyped as part of a GWA.159 The genotyping had been undertaken by means of Sentrix HumanHap300 and Sentrix HumanHap240 platforms (Illumina).158,161 The fifth SNP (rs16901979 in 8q24) was imputed from the adjacent genotyped SNPs at 8q24.^190^

9-SNP panel. In the study of Helfand, et al.,191 it is stated that genotyping was done by deCODE and reference is given to previous papers describing genotyping methods, quality control, and genotyping accuracy (5 companion papers).159,160,162,165,205 The methods include the Illumina Infinium Human Hap300 SNP chip, for which it is stated that samples with a call rate of <98 percent were excluded from analysis.159,160,162,165 In addition, the Centaurus (Nanogen) platform was used159,160,162,165,205 and the concordance rate of SNPs genotyped by both the Illumina and Centaurus methods was stated to be >99.5 percent.159,160 It is also stated that all genetic variants were in HWE.191

17-SNP panel. In the Chicago-St. Louis study,199 as for the 9-SNP panel, it is stated that genotyping was also done by deCODE and reference is given to the same companion papers describing genotyping methods, quality control, and genotyping accuracy.159,160,162,165,205 It is also stated that all 17 genetic variants were in HWE in controls.199

11-SNP panel. This panel was genotyped using the Mass ARRAY QGE iPLEX system (Sequenom).192 A call rate of 98.3 percent was also reported, with an average concordance rate for duplicate SNPs of 99.8 percent, and the genotypes for each SNP conformed to HWE in controls.192 It was not reported whether genotyping was done blind to case-control status.

14-SNP panel. In the Swedish samples in this study, this panel was genotyped using the Mass ARRAY QGE iPLEX system (Sequenom).193 A call rate of 98.3 percent and a concordance rate between duplicate samples included in each-96-well plate of 99.8 percent was reported. For the samples from the PLCO Trial included in this study, it is stated that 13 SNPs had been genotyped already as part of a companion paper,161 and one (rs16901979 in 8q24) was imputed. In the PLCO samples, genotyping was undertaken by means of Sentrix® HumanHap300 and Sentrix HumanHap240 platforms (Illumina).158,161 It is stated that tests for HWE in control participants in each of the two sets of samples were made, but results are not presented. It was not reported whether genotyping was done blind to case-control status.

16-SNP panel. This panel was genotyped using the Mass ARRAY QGE iPLEX system (Sequenom).201 A call rate of 98.3 percent was reported, with an average concordance rate for duplicate SNPs of 99.8 percent. As the study examined survival in prostate cancer cases, conformity of the genotypes to HWE was only assessed in the cases; each SNP was stated to be in equilibrium.201

28-SNP panel. No specific information was presented in the article where this panel was reported.198

Three SNPs in 8q24. The three SNPs included in this test were part of 12 SNPs at 8q24 that were genotyped using the Mass ARRAY QGE iPLEX system (Sequenom), with a call rate of >98 percent and an average concordance rate between duplicate samples included in each-96-well plate of >99 percent.194 Genotype proportions were consistent with HWE in controls.

4-SNP test: KLK2, HPC1, TNF, ETV1 and 8q24, 17q24, TNF, ETV1. The Sequenom iPLEX technology was applied in the genotyping of the Canadian study used to develop these tests. The call rate was >90 percent for 25 SNPs; six of these were not in HWE and were excluded from further analysis.195 The call rate of SNPs significantly associated with prostate cancer was >95 percent.

Test for three SNPs in steroid hormone pathway genes. The three-SNP test in non-Hispanic whites was developed on the basis of the genotyping of 120 SNPs in the steroid hormone pathway by different methods.196 One hundred and four of the SNPs were genotyped using the GoldenGate assay (Illumina), four by TaqMan, and the remainder by methods described in four publications.109,211-213 It is stated that >80 percent of SNPs were successfully genotyped in >90 percent of the samples. Three SNPs failed (rs632148 within SRD5A2; rs280663 in HSD97B3; rs10877012 in CYP27B1) and one was not polymorphic (rs9332900 in SRD5A2). Three of the remaining SNPs were not in HWE in non-Hispanic whites and were excluded from the analysis of this ethnic group.

Test for two SNPs in steroid hormone pathway genes. The two-SNP test in Hispanic whites was developed on the basis of the genotyping of 120 SNPs in the steroid hormone pathway by different methods.196 One hundred and four of the SNPs were genotyped using the GoldenGate assay (Illumina), four by TaqMan, and the remainder by methods described in four publications.109,211-213 It is stated that >80 percent of SNPs were successfully genotyped in >90 percent of the samples. Three SNPs failed (rs632148 within SRD5A2; rs280663 in HSD97B3; rs10877012 in CYP27B1) and one was not polymorphic (rs9332900 in SRD5A2). Two of the remaining SNPs were not in HWE in Hispanic whites and were excluded from the analysis of this ethnic group.

6-SNP panel. This panel was developed to predict risk for prostate cancer in two sets of samples, and to predict risk for prostate cancer mortality in three, on the basis of genotyping six 8q24 and two 17q variants.197 The Sequenom iPLEX technology was used to genotype samples from the Physicians' Health Study and the Gelb Center; there was >99 percent concordance for six SNPs that were assessed on a subset (n=1,370) of specimens twice.197 The Applied Biosytems (ABI) SNPlex Genotyping System was used to genotype the samples from King County, Washington. None of the eight SNPs violated HWE in either set (Physicians' Health Study or King County, Washington) of controls. The call rate for the eight SNPs genotyped was >94 percent.

35-SNP panel. This panel was developed by genotyping 36 SNPs validated in previous studies using matrix-assisted laser desorption/ionization time-of-flight (MALDI-TOF) mass spectrometry based on allele-specific primer extension using the Sequenom iPLEX technology.200 Genotyping rs2660753 (at 3p12) failed completely. For the remaining 35 SNPs, a 98.6 percent average call rate was reported. Hardy-Weinberg equilibrium was assessed in controls, no departure from HWE was observed (per an email from H. Grönberg, M.D., Ph.D. ( Henrik.Gronberg@ki.se) on February 2, 2012). The genotyping was performed at a core mutation analysis facility in Huddinge and was fully blinded to the case-control status (clarified in emails from H. Grönberg, M.D., Ph.D. ( Henrik.Gronberg@ki.se), and M. Aly, M.D. ( markus.aly@ki.se) on February 2, 2012).

deCODE ProstateCancer test. The company's Web site states that the deCODE ProstateCancer test is performed by Illumina I-Select Bead Chip method – and based on proprietary Illumina technology using DNA amplification hybridization and fluorescent detection.208 Greater than 99.9 percent accuracy is claimed.

### 3 What are the sources of variation in accuracy or analytical validity across different test panels?

No evidence to address this question was identified.

## KQ2 What is the clinical validity of available SNP-based panels designed for prostate cancer risk assessment?

### 1 How well do available SNP-based genotyping platforms predict the risk of prostate cancer in terms of

#### a stratifying future risk and/or screening for current disease?

5-SNP panel (Focus 5) with and without inclusion of family history. Zheng, et al.,188 developed a model for the cumulative effect of five SNPs, selected as the most significant of 16 SNPs genotyped in five chromosomal regions (three at 8q24, and two at 17q). The number of genotypes associated with prostate cancer was counted for each subject and showed a significant trend of association, with the odds ratio (OR) for four or more genotypes compared with none being 4.47 (95% CI, 2.93 to 6.80, adjusted for age, geographic region, and family history). When family history was included in the risk score for each subject, the OR for five or more factors (genotype or family history) was 9.96 (95% CI, 3.62 to 24.72, adjusted for age and geographic region). Receiver operating curves were calculated. The area under the curve (AUC) for a model including age and geographic region was 57.7 percent (95% CI, 56.0 to 59.3), for a model adding family history to these factors was 60.8 percent (95% CI, 59.1 to 62.4), and for a model further adding in the number of genotypes associated with prostate cancer was 63.3 percent (95% CI, 61.7 to 65.0). These data were also presented in a later paper focusing on the development of a 28-SNP panel.198 In the later analysis, the sensitivities and specificities of a risk score combining the five SNPs and family history in first-degree relatives were presented for cutoffs of onefold, twofold, and threefold the median risk score (Table 4). As would be expected, sensitivity decreased and specificity increased with increasing cutoffs of absolute risk. The positive predictive value of the five SNPs (family history excluded) was 34 percent.

Table 4 Sensitivity and specificity for absolute risk of prostate cancer for risk score based on 5-SNP and family history (FHx) in first-degree relatives in Swedish study198

| 5-SNP + FHx
Cutoff | Sensitivity | Specificity
Onefold median | 0.53 | 0.61
Twofold median | 0.16 | 0.93
Threefold median | 0.05 | 0.98

The model was tested in independent data from men of European origin in King County, Washington,189 in data from the Johns Hopkins Hospital and the PLCO Cancer Screening Trial,190 in a Canadian study,195 and in a study in which cases underwent radical prostatectomy in a hospital in Chicago.191 The pattern of association with risk score was attenuated compared with the original study of Swedish data,188 with the OR for four or more genotypes compared with the reference category of no risk genotypes being 3.36 (95% CI, 1.90 to 6.08, adjusted for age and family history) in King County, 2.42 (95% CI, 1.4 to 4.1) in the Canadian study, 2.84 (1.30 to 6.21) in Johns Hopkins Hospital, 3.09 (95% CI, 1.62 to 5.90) in the PLCO Trial, and 3.19 (95% CI, 1.85 to 5.50, adjusted for age) in Chicago. In the Canadian study, the AUC for a baseline model that included age, family history of prostate cancer, ethnicity, urinary symptoms, PSA, free: total PSA ratio, and DRE was 72 percent (95% CI, 70 to 74), and with the addition of five SNPs, 73 percent (95% CI, 71 to 75).195 In these studies, the proportion of controls with four or more risk genotypes ranged between 1.6 percent190 and 3.4 percent,191 while the population with five or more risk factors (one of which could be family history of prostate cancer) was 0.3 percent or less.188-190

When family history was included in the risk score, the ORs for five or more risk factors compared with none was 4.92 (95% CI, 1.58 to 18.53, adjusted for age) for King County,189 and 20.68 (95% CI, 2.61 to 163.85) for the PLCO trial.190 In the King County data, the AUC for a model including age, serum PSA level, and history of prostate cancer in a first-degree relative was 63 percent, which increased to 66 percent when the five SNPs were added (difference 3 percent, 95% CI, -12 to +6); this difference was not statistically significant.189

9-SNP panel. Helfand, et al.191 extended the 5-SNP model, adding four variants at 2p15, 10q11, 11q13, and Xp11. The OR associated with having six or more of the nine risk genotypes was 5.75 (95% CI, 2.50 to 13.24), and the proportion of controls in the category of highest risk was 2.5 percent. For the model with five genetic variants, the crude AUC was 58 percent, and with adjustment for age, 65 percent. With inclusion of the four additional variants, the AUCs were 61 percent and 66 percent, respectively.

17-SNP panel. In the Chicago-St. Louis study (Helfand et al.),199 the 9-SNP model was modified by changing one variant at 2p15, and adding one variant at 3q21.3, 11q13, 17q12, 19q13.2, and two at 5p15 and 8q24. The study differed from the others in that it was limited to men with a PSA level <4.0ng/ml and with normal DRE, and cases were limited to clinical stage T1c. Compared with men who had four or fewer variants, the OR for men with 11 or more variants was 10.6 (95% CI, 2.7 to 42.0), and the proportion of controls in this highest risk category was 2.5 percent. When history in first-degree relatives was added to the risk score, compared to men with zero to five variants/family history, the OR for men with 11 or more variants was 11.2 (95% CI, 4.3 to 29.2), and the proportion of controls in this highest risk category was 3.2 percent. The AUC for the model including all the carrier numbers of the 17 SNPs was 0.66; this was not significantly different from an AUC of 0.62 for age alone. The AUC of a model containing the 17 SNPs and family history was 0.71, which was statistically significantly higher than the model based on age alone.

11-SNP panel. Zheng, et al.,192 examined the effect of including 14 additional SNPs in the same Swedish study participants as in the original 5-SNP model.188 On the basis of an SNP by SNP analysis, 12 remained associated with prostate cancer risk after adjustment for age, family history, geographic region, and the other SNPs. However, one of these SNPs was not included in further analysis because it was originally discovered in this study population and “has not been extensively confirmed in other study populations.”192 Thus, further evaluation focused on counts of risk alleles for 11 SNPs and family history. The AUC for a model involving age only was 58 percent (95% CI, 56 to 59), for age and family history was 61 percent (95% CI, 59 to 62), and for age, family history, and all eleven SNPs was 65 percent (95% CI, 63 to 66). Stratified analysis of data on sensitivity and specificity by number of risk factors did not show differences by disease aggressiveness or age at diagnosis. These data were also presented in a later paper focusing on the development of a 28-SNP panel.198 In the later analysis, the sensitivities and specificities of a risk score combining the 11 SNPs and family history in first-degree relatives were presented for cutoffs of onefold, twofold, and threefold the median risk score (Table 5). As would be expected, sensitivity decreased and specificity increased with increasing cutoffs of absolute risk. The positive predictive value of the 11 SNPs (family history excluded) was 37 percent.

Table 5 Sensitivity and specificity for absolute risk of prostate cancer for risk score based on 11-SNP and family history (FHx) in first-degree relatives in Swedish study198

| 11-SNP + FHx
Cutoff | Sensitivity | Specificity
Onefold median | 0.54 | 0.62
Twofold median | 0.18 | 0.92
Threefold median | 0.07 | 0.98

14-SNP panel. The Swedish data were also investigated in development of a prediction model of absolute risk for prostate cancer using 14 SNPs and family history, and using data for the PLCO trial for confirmation.193 The number of risk alleles could range from zero to 27 (because one of the risk alleles was on the X chromosome), with the mode being 11 for controls. In the Swedish data, the OR for prostate cancer in men who had ≥14 risk alleles and positive family history (which occurred in 1 percent of control men) compared with men with 11 risk alleles and no family history of prostate cancer was 4.92 (95% CI, 3.64 to 6.64). The corresponding OR for the PLCO trial data was 3.88 (95% CI, 2.83 to 5.33). In the Swedish data, the risk did not differ between aggressive and nonaggressive disease. With regard to absolute risk in Sweden, a 55 year old man with ≥14 risk alleles and a positive family history was estimated to have a 52 percent risk of being diagnosed with prostate cancer in the next 20 years, compared to a risk of 8 percent for men with seven or fewer risk alleles and no family history. The corresponding estimates for the men in the United States were 41 percent and 6 percent, respectively.

28-SNP panel. The Swedish data were also used in the development of a 28-SNP panel.198 The AUC for the panel was 0.62, compared with 0.61 for the 11-SNP panel, and 0.60 for the 5-SNP panel; these differences were statistically significant. The sensitivities and specificities of a risk score combining the 28 SNPs and family history in first-degree relatives were presented for cutoffs of onefold, twofold, and threefold the median risk score (Table 6). As would be expected, sensitivity decreased and specificity increased with increasing cutoffs of absolute risk. The positive predictive value (PPV) of the 28-SNPs (family history excluded) was 37 percent. When the SNPs and family history were sorted on the basis of their contribution to genetic variance, from highest to lowest, at each cutoff of onefold, twofold, and threefold population median risk, the PPV increased only slightly with increasing numbers of SNPs.

Table 6 Sensitivity and specificity for absolute risk of prostate cancer for risk score based on 28-SNP and family history (FHx) in first-degree relatives in Swedish study198

| 28-SNP + FHx
Cutoff | Sensitivity | Specificity
Onefold median | 0.55 | 0.62
Twofold median | 0.23 | 0.91
Threefold median | 0.11 | 0.97

Three SNPs in 8q24. One study in the Johns Hopkins Hospital investigated multiple variants of 8q24 in men with prostate cancer who had at least two additional first-degree relatives with prostate cancer, men who did not fall into this category, and controls.194 To assess the combined effects of variants in three regions of 8q24, one variant from each region was selected. Compared to men with no risk genotype, the OR of prostate cancer for men with 2+ affected first-degree relatives for two or more risk genotypes was 2.94 (95% CI, 1.68 to 5.15), and for prostate cancer without such a family history was 2.23 (95% CI, 1.52 to 3.28).

4-SNP test: KLK2, HPC1, TNF, ETV1. In a Canadian study,195 in addition to examining the 5-SNP model of Zheng, et al.,188 a model comprising four SNPs, one each in KLK2, HPCI, TNF, and ETV1 was evaluated. The OR associated with presence of all four variants compared with none was 2.53 (95% CI, 1.6 to 4.1). The proportion of controls that had variants of all four SNPs was 3.2 percent. The AUC for the baseline model that included age, family history of prostate cancer, ethnicity, urinary symptoms, PSA, free: total PSA ratio, and DRE was 72 percent (95% CI, 70 to 74), and with the addition of the four SNPs was 73 percent (95% CI, 71 to 74).

4-SNP test: 8q24, 17q24, TNF, ETV1. In the same Canadian study,195 a model comprising four SNPs, one each from 8q24, 17q24.3, TNF, and ETV1, was evaluated. The OR associated with presence of all four variants compared with none was 6.07 (95% CI, 2.0 to 18.5). The proportion of controls that had variants of all four SNPs was 0.3 percent. The AUC for the baseline model that did not include SNPs (see above) was 72 percent, and with the four SNPs included was 74 percent (95% CI, 72 to 76). Using two thirds of the data, the investigators developed a nomogram that incorporated these SNPs, age, family history of prostate cancer, ethnicity, urinary voiding symptom, PSA level, free: total PSA ratio, and DRE in predicting all prostate cancer, and predicting prostate cancer with a Gleason score of 7 or more. Predicted and actual probabilities were compared in the remaining one third of the data, and the incremental drop in AUC for each predictor variable when removed from the nomogram model was assessed. The incremental drop was greater (1.4 percent) for the SNP combination than PSA (0.1 percent), family history of prostate cancer (0.3 percent), urinary voiding symptom (0.1 percent), and DRE (1.0 percent), but not age (2.2 percent) or free: total PSA ratio (6.6 percent).

Test for three SNPs in steroid hormone pathway genes. Beuten, et al.,196 examined SNPs in the steroid hormone pathway. They presented information on the cumulative effect of three risk variants, (one in HSD3B2, two in CYP19) in non-Hispanic whites. There was a trend with an increasing number of risk genotypes. The OR for three risk genotypes compared with none was 2.87 (95% CI, 1.64 to 5.02, adjusted for age), with 3.6 percent of controls in the category of highest risk.

Test for two SNPs in steroid hormone pathway genes. In the investigation of SNPs in the steroid hormone pathway described in the preceding subsection, Beuten, et al.,196 presented information on the cumulative effect of two risk variants (one in CYP19, different from those in non-Hispanic whites, one in CYP24A11) in Hispanic whites. Again, there was a trend with an increasing number of risk genotypes. The OR for two risk genotypes compared with none was 4.58 (95% CI, 2.19 to 9.61, adjusted for age), with 5.6 percent of controls in this category of risk.

6-SNP test. Penney, et al.,197 evaluated eight SNPs, six in 8q24 and two in 17q, in data from the Physicians' Health Study (PHS) and from King County, Washington. Four of the 8q24 and the two 17q SNPs were significantly associated with prostate cancer in the two data sets, and the association with a risk score obtained by adding up the alleles was evaluated. The risk of prostate cancer increased by 19 percent for each additional risk allele in the PHS, and 23 percent in King County.

35-SNP panel. Aly, et al.,200 focused their analyses relating to clinical validity of a 35-SNP panel on men with a PSA level ≤10 ng/ml as they considered that there is most debate over recommending a prostate biopsy in this group than in men with a higher PSA level. A genetic score was calculated by summing the number of risk alleles (0,1, or 2) at each of the 35 SNPs multiplied by the logarithm of the OR for that SNP. In univariate analysis, the OR associated with this score was 1.93 (95% CI, 1.85 to 2.01), with an AUC of 0.61 (95% CI, 0.59 to 0.63). In multivariate analysis, adjusting for PSA, the ratio of free-to-total PSA, age, and family history, the OR was 1.52 (95% CI, 1.45 to 1.59). The AUC for PSA, the ratio of free-to-total PSA, and age was 0.63 (95% CI, 0.60 to 0.65); the addition of family history increased this to 0.64 (95% CI, 0.62 to 0.66) and adding both family history and the genetic score increased the AUC to 0.67 (95% CI, 0.65 to 0.70).

Different risk cutoffs were assessed for: 1) the model comprising PSA, the ratio of free-to-total PSA, age, and family history; 2) the addition of the genetic score to this model; and, 3) a hypothetical genetic model based on a score variable constructed from SNPs explaining 100% of the population genetic risk. Comparisons were made of how these would affect the numbers of biopsies performed and cancer detected per 1,000 men with a clinical prostate biopsy (Table 7). The addition of the 35 SNPs (Model 2) to the factors included in Model 1 would reduce the number of biopsies conducted but increase the number of missed cancers. For the hypothetical genetic model (Model 3), the number of biopsies would be further reduced compared with Model 2, and the increase in proportion of missed cancers reduced.

Table 7 Comparison of effects on biopsies conducted and cancer detected per 1,000 men with a clinical prostate biopsy between three models of risk prediction for prostate cancer and two cutoffs

Model | Cutoff | Biopsies | | | Cancers
Model | Cutoff | Conducted | Avoided | % Avoided | Detected | Missed | % Missed
Biopsies conducted and cancers detected | | 1000 | 0 | 0 | 365 | 0 | 0
1. PSA, the ratio of free-to-total PSA, age, and family history | 20 | 949 | 51 | 5.1 | 352 | 13 | 3.6
1. PSA, the ratio of free-to-total PSA, age, and family history | 25 | 871 | 129 | 12.9 | 338 | 27 | 7.4
2. PSA, the ratio of free-to-total PSA, age, family history, and genetic score | 20 | 878 | 122 | 12.2 | 344 | 21 | 5.8
2. PSA, the ratio of free-to-total PSA, age, family history, and genetic score | 25 | 773 | 227 | 22.7 | 321 | 44 | 12.1
3. Hypothetical genetic model | 20 | 745 | 255 | 25.5 | 348 | 17 | 4.7
3. Hypothetical genetic model | 25 | 686 | 314 | 31.4 | 340 | 25 | 6.8

deCODE ProstateCancer test. The deCODE Prostate Cancer Web site states that the predictive accuracy of the 27-SNP ProstateCancer test panel, the 9-SNP subset for African-American men, and the 12-SNP subset for men of East Asian descent is essentially independent of, and therefore complements, the risk confirmed by family history of the disease.208 The validity is reported to be based on the evaluation of risks associated with single SNPs; it is stated that the validity of multiplying together the risk conferred by different markers is based on the lack of significant interaction or overlap of impact between markers in two studies.165,168

#### b Distinguishing between clinically important and latent/asymptomatic prostate cancer

5-SNP panel. In a case-only analysis of combined data from the Swedish, Johns Hopkins Hospital, and PLCO Trial participants, there was no statistically significant association between the five genetic variants, Gleason score, aggressiveness of prostate cancer,214 or age at diagnosis.190

14-SNP panel. In the Swedish data investigated in the development of a prediction model of absolute risk for prostate cancer using 14 SNPs and family history, the OR for aggressive prostate cancer in men who had ≥14 risk alleles and positive family history compared with men with 11 risk alleles and no family history of prostate cancer was 4.77 (95% CI, 3.41 to 6.69).193 The corresponding OR for nonaggressive prostate cancer was 5.05 (95% CI, 3.66 to 6.96). In addition, the risk associated with each increase in the number of risk alleles did not differ between aggressive and nonaggressive disease.

11-SNP panel. In the analysis of Zheng, et al.,192 which developed a model comprising counts of risk alleles for 11 SNPs and family history, stratified analysis of data on sensitivity and specificity by number of risk factors did not show differences by disease aggressiveness or age at diagnosis.

35-SNP panel. In the study of Aly, et al.,200 aggressive disease was defined as T3-4 N1 M1 or Gleason 4+3 and higher, and nonaggressive disease as T0-2 N 0/X M 0/X or Gleason 3 +=4 and lower. The increase in AUC for aggressive disease between a SNP-based model (35-SNPs) and a non-SNP-based model based on PSA, the ratio of free-to-total PSA, age, and family history was not statistically significant.

#### c How well do available SNP-based genotyping panels predict prognosis in individuals with a clinical diagnosis of prostate cancer?

5-SNP panel (Focus 5) with and without inclusion of family history. In the study in King County,189 described above, the predictive ability of the SNP panel for prostate cancer specific mortality over an average length of followup of 7.6 years was evaluated. There were 45 deaths among 1,207 men with followup data; there was no association with the SNPs individually or in combination, and they did not increase the AUC for a model that included age at diagnosis, serum PSA at diagnosis, Gleason score, and tumor stage (difference in AUC between model including SNPs compared to one without 0.5 percent, 95% CI, -1 to +2).

6-SNP test. In a survival analysis of the six SNPs found to be associated with prostate cancer in the data from the PHS and King County using the Cox proportional hazards model, there was no significant association between these variants and prostate cancer mortality.197 In addition, comparison was made between prostate cancer deaths and men alive more than 10 years after diagnosis in a combined analysis that included both of these samples, together with a series of cases from the Dana-Farber Harvard Cancer Center diagnosed over the period from 1976 to 2007. The total number of risk alleles was not associated with mortality.

16-SNP panel. In a population-based study of survival after prostate cancer diagnosis in 2,875 men in Sweden over an average of 4.9 years (range 3.7 to 6.8 years), there was no association between prostate cancer mortality in a comparison with the average number of risk alleles, in a test for trend with an increasing number of risk alleles, or in relation to specific individual variants within the panel.201

None of the studies reported above presented data on risk reclassification or performance in simulation analyses.

### 3 What other factors (e.g., race/ethnicity, gene-gene interaction, gene-environment interaction) affect the predictive value of available panels and/or the interpretation of their results?

Beuten, et al.,196 developed separate tests for SNPs in steroid hormone pathway genes for non-Hispanic whites and Hispanic whites (see above).

deCODE markets the ProstateCancer test, which tests for 27 genetic variants (Table 13) associated with prostate cancer in men of European descent (including the five SNPs included in the Focus 5 test), a subset of nine variants for African-American men, and a subset of 12 variants for men of East Asian descent; the specific variants in the subsets are not specified in the Web site (www.decodhealth.com/prostate-cancer).208

## KQ3 What is the clinical utility of available SNP-based panels designed for prostate cancer risk assessment?

### Process of care

#### 1 Does the use of panels alter processes of care and behavior?

a. screening or management decisions, and the appropriateness of these decisions, by patients and/or providers
b. alteration in health-related behaviors of patients (e.g., adherence to recommended screening interventions and/or other lifestyle changes)?

No data addressing this question were identified.

### Health outcomes

#### 2 Does the use of panels lead to changes in health outcomes?

a. all-cause mortality
b. cancer-specific mortality
c. morbidity

### And do any changes vary by race or ethnicity?

No data addressing this question were identified.

### Harms

#### 3 Does the use of panels lead to harms?

a. psychological harms
b. other negative individual impacts (e.g., discrimination) and do any such harms vary by race or ethnicity?

No data addressing this question were identified.

### Costs

#### 4 What is known about the costs, cost-effectiveness, and/or cost utility of using SNP-based panels for prostate cancer risk assessment, compared to current practice?

No data addressing this question were identified.

## Quality Assessment of Individual Studies

All included studies were related to clinical validity, which usually lends itself to a medical test framework for quality assessment. However, we decided to use the Newcastle-Ottawa Scale (NOS)185 (Table 14a) because all but one of the studies had a case-control design (the exception being a cohort study of prostate cancer survival201), and because it is not clear how well the QUADAS186 tool would apply to genetic tests. We supplemented this with selected items from the QUADAS186 tool to assess the risk prediction aspect of the included studies. These were: (1) whether the spectrum of participants was representative of the patients who would receive the test in practice; (2) whether the selection criteria were clearly described; and, (3) whether un-interpretable, indeterminate, or intermediate test results were reported (Table 14b). Other QUADAS186 criteria considered when assessing the risk of bias of the studies included whether or not: 1) the whole sample or a random selection of the sample received verification using the reference standard; 2) participants received the same reference standard regardless of the index test result; 3) the reference standard was independent of the index test; 4) the execution of the index test was described in sufficient detail to permit its replication; and, 5) the same clinical data were available when the test results were interpreted as would be available when the test is used in practice.

Table 14

Table 14a Newcastle-Ottawa Scale:185 Case-control studies

| Study
Question | Zheng188 | Salinas189 | Sun190 | Sun190 JHH | Helfand191 | Zheng192 | Xu193 | Sun194 | Nam195 | Beuten196 | Penney197 PHS & FHCRC | Penney197 Gelb Center companion 227 | Aly200 | Helfand199 | Sun198
Is the case definition adequate? A* = yes, with independent validation B = yes, e.g., record linkage or based on self-reports C = no description | A* | A* | C | C | A* | A* | PR | B | A* | A* | A* | C | B | C | A*
Representativeness of the cases A* = consecutive or obviously representative series of cases B = potential for selection biases or not stated | B | A* | A* | A* | A* | A* | PR | A* | A* | B | B | B | B | B | B
Selection of Controls A* = community controls B = hospital controls C = no description | A* | A* | A* | B | C | A* | PR | B | B | A* | A* | C | A* | C | A*
Definition of Controls A* = no Hx of disease (endpoint) B = no description of source | B | A* | B | B | B | B | PR | B | A* | A* | A* | B | A* | A* | B
Comparability of cases and controls on the basis of the design of analysis A* = study controls for (select most important factor) B* = study controls for any additional factor | A*B | A*&B* | A*&B* | A* | A* | A*&B* | PR | A*&B* | A*&B | A*&B* | A*&B* | A* | A*&B* | A* | A*&B*
Ascertainment of exposure: quality control & blinding A* = secure record (e.g., surgical records) B = structured interview where blind case/control status C = interview not blinded to case/control status D = written self-report or medical record only E = no description | A* | A* | E | E | E | E | PR | A* | E | D | A* | A* | A* | A* | E
Same method of ascertainment for cases & controls A* = yes B = no | B | B | A* | A* | B | B | PR | B | A* | A* | A* | A* | A* | B | PR
Non-Response rate A* = same rate for both groups B = nonrespondents described C = rate different and no designation | B | B | C | C | C | B | PR | C | C | C | C | C | C | C | C
NOS Star Rating (out of 9) | 5 | 7 | 5 | 3 | 3 | 5 | NA | 4 | 6 | 6 | 7 | 3 | 6 | 2 | 4

Abbreviations: FHCRC = Fred Hutchinson Cancer Research Center; Hx = history; JHH = Johns Hopkins Hospital; NA = not available; PHS = Physician's Health Study; PR = previously reported

Table 14b Newcastle-Ottawa Scale:185 Cohort studies

Study | Representativeness of the exposed cohort A* truly representative of the average prostate cancer patient in the community B* somewhat representative C selected group of users (volunteers) D no description of derivation of cohort | Selection of the non exposed cohort A* from same community as exposed B from different source C no description | Ascertainment of exposure A* secure records (surgical) B* structured interview C written self report D no description | Demonstration that outcome of interest was not present at start of study A* yes B no | Comparability of cohorts on the bases of the design or analysis A* most important factor study controls for B* additional factor | Assessment of outcome A* independent blind assessement B* record linkage C self report D no description | Was follow-up long enough for outcomes to occur A* yes B no | Adequacy of follow up of cohorts A* complete follow up B*small number lost (%) or description of those lost, C % lost and no description of lost D no statement | NOS Star Rating (out of 9)
Wiklund 201 | A* (PR) | A* | A* | A* (PR) | A* | B* | A* | A* | 8

Table 14c Selected items from QUADAS186

Question | Zheng188 | Salinas189 | Sun190 | Helfand191 | Zheng192 | Xu193 | Sun194 | Nam195 | Beuten196 | Penney197 | Penney197 | Penney197 | Aly200 | Helfand199 | Sun198 | Wiklund201
Spectrum of participants representative of the patients who would receive the test in practice | yes | yes | yes | no | yes | NA | no | no | yes | no (PHS) | yes (FHCRC) | UC (Gelb Center) | yes | yes | yes | yes
Selection criteria clearly described | yes | yes | yes | no | yes | NA | UC | yes | yes | yes | yes | yes^*^ | yes | yes | yes | yes
Reporting of uninterpretableindeterminate, or intermediate test results | yes | yes | no | no | yes | NA | no | UC | no | no | no | no | yes | yes | yes | yes

* yes, if look at companion

Abbreviations: FHCRC = Fred Hutchinson Cancer Research Center; NA=not applicable; PHS = Physician's Health Study, UC=unclear

The reference standard for cases was histopathological diagnosis in all of the studies, but checking for latent or undiagnosed cancer was not conducted in control groups with two exceptions.195,200 Autopsy studies in men over 50 years of age who had died from other causes have demonstrated a frequency of histologically proven prostate cancer of 30 to 40 percent.54-60 However, there are clearly ethical constraints to taking prostate tissue samples in asymptomatic men in order to exclude an undiagnosed disease. In one of the studies, controls were selected from the same group of men referred to prostate cancer centers who had either a PSA value ≥4.0ng/ml or an abnormal DRE and who had no biopsy evidence of prostate cancer.195 The results of the clinical validity evaluation of the 5-SNP panel in this study were similar to those of the other studies in which this panel was evaluated.189-191 In all of the studies, it seems unlikely that the index test result affected the decision to undertake prostate biopsy, or the interpretation of histopathological examination of biopsy specimens. However, since all of the studies were conducted in research contexts, it is not clear that decisionmaking incorporated the same clinical data as would have been available in routine practice.

The execution of the genotyping component of the index test was adequately described in all but one198 of the studies (see section on analytic validity). Almost all of the studies related to participants of European origin, and those that did not adjusted for ethnicity or conducted analyses restricted to participants of European origin. This is likely to have limited the risk of bias resulting from population stratification; that is, the presence within a population of subgroups among which allele (or genotype, or haplotype) frequencies and disease risks differ.215-218 However, some of the other variables included in risk scores may have been prone to differential error because of the retrospective case-control design used in all but the PLCO Trial,193,203 the PHS,197 and the San Antonio cohort.196

By combining the results of the NOS185 evaluation and the QUADAS186 criteria for the individual studies, all studies of the 5-SNP panel were found to have a moderate risk of bias. Based on three selected domains in the NOS185 (selection of controls, comparability of cases and controls, method of ascertainment of cases and controls), along with limited data about genotyping methods and quality control, lack of specification of which candidate nongenetic variables were initially examined or considered for inclusion in the risk models, and lack of information about how these variables were assessed, the overall risk of bias of was assessed as being at least ‘moderate’. Using the same approach, the assessments of the other 14 panels were based on single studies, reported in eleven articles,191-201 and these were also all considered to have at least a moderate risk of bias.

## Rating the Body of Evidence

Four domains were considered in the assessment of overall strength of evidence (SOE) for the SNP panels identified. These were risk of bias (internal validity of the studies), the consistency of findings, directness (how closely the tests were applied in a way which resembles routine practice), and precision (whether the estimates allow clinically useful conclusions).

For the domain of internal validity, all studies were assessed as having at least a moderate risk of bias. For the domain of consistency, it is impossible to assess results for panels evaluated in single studies only. For the Focus 5 panel, where there were several studies, the data did not permit development of an ROC curve, and therefore consistency could also not be assessed quantitatively. For models containing the five SNPs included in the Focus 5 panel, but with diverse other variables included, the AUC ranged between 63 percent and 73 percent.188,193,195 Compared with the models that did not include the SNPs, the 5 SNPs increased the AUC by 1 to 3 percent.

For the domain of directness, all studies were conducted in a research context, no panel being applied in a setting that might be considered close to routine clinical practice. As well as presenting difficulty in assessing generalizability to a ‘typical’ clinical approach, this meant that none of the tests were explicitly evaluated in a medical test framework. Specifically, the case-control design meant there was no meaningful comparison of any SNP panel against a routine clinical alternative ‘test’. Finally, the assessment of the precision domain requires a clear idea of clinically meaningful differences between levels of sensitivity, specificity, AUC, and other accuracy metrics (i.e., how much difference in one of these would make a ‘real’ difference in clinical or patient decisionmaking). This area of evaluation appears to be underdeveloped in the clinical literature, and the studies evaluated shed no light on this aspect. We were therefore unable to offer a valid assessment of this domain.

We are unable to assess the extent of publication bias in this review. We contacted a comprehensive list of companies we considered most likely to be developing SNP panels for commercial application, and received no responses. It is possible that unpublished data exist to support the clinical validity of one or more of the SNP panels reviewed here, or of other SNP panels which were not identified in this report. If so, this review's conclusions would be unduly negative. However, this would be an unlikely scenario, since publication bias is usually considered to lead to selective reporting of studies with systematically larger effect sizes than is actually the case.219 Only papers published in English were included. There is no empirical evidence of the effects of language restriction on genetic risk prediction studies. Although there is some empirical evidence of systematic differences in effect sizes of genetic associations reported in studies in Asian populations published in English and in Chinese, it is not clear that these differences are due to publication bias.220 Moreover, there is evidence of considerable overlap of publications in English and Chinese medical journals on the same studies.221 In the literature on randomized controlled trials, restriction to English language publications does not appear to bias estimates of effectiveness of conventional interventions.222

Overall, it is unlikely that any of the biases identified would be sufficient to alter the interpretation of the findings from (at best) inadequacy of evidence to clearly positive supporting evidence for any of the SNP panels reviewed.

For characteristics of included studies see Tables 8–10. The Focus 5 test is reported in Table 11. Summary of SNPs and other variables included in test panels is reported in Table 12. Table 13 reports genetic variants tested for by deCODE ProstateCancer and Table 14 reports case studies on the Newcastle-Ottawa Scale.