# Technical Expert Panel

Rodney Breau, M.D.

Urological Oncology Fellowship

Mayo Clinic

Rochester, MI

Phillip Febbo, M.D.

Department of Medicine, Leader, UCSF Helen Diller Family Comprehensive Cancer Center

San Franscisco, CA

Ted Ganiats, M.D.

Department of Family and Preventitive Medicine

Univeristy of California San Diego

La Jolla, CA

Roger Klein, M.D., J.D., FCAP

Medical Director

Molecular Oncology at BloodCenter of Wisconsin

Milwaukee, WI

Daniel Mercola, M.D., Ph.D.

Pathology and Laboratory Medicine, Director, Translation Cancer Biology

University of California

Irvine, CA

Ken Offit, M.D.

Chief, Clinical Genetics Service

Memorial Sloan-Kettering Cancer Center

New York, NY

Sue Richards, Ph.D.

Oregon Health & Science Univeristy

Portland, OR