# Data Abstraction Forms

SNP Screening Forms

SNP Data Abstraction Form

NEWCASTLE - OTTAWA QUALITY ASSESSMENT SCALE CASE-CONTROL STUDIES

NEWCASTLE - OTTAWA QUALITY ASSESSMENT SCALE COHORT STUDIES

The QUADAS tool