# Search Strings

## Medline

1. Prostatic Neoplasms/
2. *Neoplasms/
3. ((prostate or prostatic) adj2 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
4. 1 or 2 or 3
5. Polymorphism, Single Nucleotide/
6. SNP?.tw.
7. *Genetic Predisposition to Disease/ge [Genetics]
8. or/5-7
9. 4 and 8
10. limit 9 to english language
11. limit 10 to (comment or editorial)
12. 10 not 11

## EMBASE

1. Polymorphism, Single Nucleotide/
2. SNP?.tw.
3. exp *genetic predisposition/
4. 1 or 2 or 3
5. exp prostate cancer/
6. *Neoplasms/
7. ((prostate or prostatic) adj2 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
8. 5 or 6 or 7
9. 4 and 8
10. limit 9 to english language
11. limit 10 to (editorial or note)
12. 10 not 11

## Cochrane Central Register of Controlled Trials

1. Prostatic Neoplasms/
2. *Neoplasms/
3. ((prostate or prostatic) adj2 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
4. 1 or 2 or 3
5. Polymorphism, Single Nucleotide/
6. SNP?.tw.
7. *Genetic Predisposition to Disease/ge [Genetics]
8. or/5-7
9. 4 and 8