# Acknowledgments

The researchers at the McMaster EPC would like to acknowledge the following people for their contributions. We are grateful to our Task Order Officer, Suchitra Iyer, for her support and guidance. Members of the technical expert panel were instrumental in the formation of the parameters and goals of this review.

We would also like to thank those who worked so conscientiously, retrieving and screening citations, abstracting data, preparing figures, and editing the report: Una Adamcic-Bistrovoda, Julianna Beckett, Jan Brozek, Patricia Carson, Chris Carvalho, Bryan Cheeseman, Roxanne Cheeseman, Mary Gauld, Natalie Gallo, Inna Gong, Mahbubul Haq, Michael Knauer, Denise Landry, Leah Macdonald, Sohel Nazmul, Maureen Rice, and Jodi Wilson.