# Results

## Results of the Literature Search

The literature search process identified 13,014 unique citations. During the abstract review process, we excluded 12,567 abstracts that did not meet one or more of the eligibility criteria (see Methods for details). At article review, we excluded an additional 351 articles that did not meet one or more of the eligibility criteria (see Appendix D, Excluded Articles). Ninety studies described in 96 articles were eligible for inclusion in the review (Figure 2). We described the information abstracted in a systematic manner, but did not conduct any meta-analyses. The outcomes were too diverse to allow for quantitative synthesis.

Figure 2 Results of the literature search

^a^ The sum of reasons for exclusion at abstract screening is greater than the total number of exclusions because each reviewer could select a different reason for exclusion.

^b^ The sum of reasons for exclusion at article screening is greater than the total number of exclusions because each reviewer could select a different reason for exclusion.

Figure 2. Results of the literature search. This figure shows the number of articles captured by the searches by database and the total number of articles screened after deduplication (11633). A total of 429 full text articles were screened for applicability and 326 were excluded for various reasons. Ninety-three articles were ultimately included in this review.

## Report Organization

We first divided the interventions into the four key target areas or into an additional category for multiple and other targets. The results section is organized into these five sections, by target area:

- Continuity, Coordination of Care, and Transitions
- Pain
- Distress
- Communication and Decisionmaking
- Interventions with multiple or other targets (this section also mostly details studies that fit into a narrower definition of quality improvement).

Each target area section is then further divided into subsections based on the Key Questions. Key Question 1a broadly addresses health care and palliative care interventions within the target area and their impact on outcomes and Key Question 1b addresses the settings of care. Key Question 2a addresses different quality improvement types and Key Question 2a addresses different models—integrative compared to consultative. Either Key Question 2a or 2b is then addressed for each section (whichever was most appropriate for the intervention types within that section—these were mutually exclusive).

The four sections focusing on individual targets are organized as follows:

- Study characteristics
- Key Question 1a (results for target): results summarized by key outcomes
- Key Question 1b: results for hospice and nursing home studies
- Key Question 2a (results for quality improvement types): results summarized by key outcomes (except for communication and decisionmaking, where Key Question 2b is addressed instead and a short summary of the results is given)
- Grading of the evidence
- Summary tables for the studies

For the last section on multiple and other targets focusing on quality improvement, since Key Question 1a was not analyzed, the results are organized somewhat differently, as follows:

- Study characteristics
- Key Question 1b: results for hospice and nursing home studies
- Key Question 2a: results summarized by quality improvement type
- Grading of the evidence
- Summary tables for the studies

Each section includes an assessment of the strength of evidence for Key Question 1 and 2, except for the strength of evidence for Key Question 1b, on settings. This strength of evidence is summarized in Appendix F.

## Description of the Types of Studies Retrieved

There were 23 studies described in 26 articles that applied to continuity and addressed Key Questions 1a, 2 and 2a; 21 studies described in 23 articles applied to pain and addressed Key Questions 1a and 2a; seven studies described distress and addressed Key Question 1a; 20 studies described communication and addressed Key Questions 1a, 2a and 2b; 19 studies described in 20 articles described multiple and other targets and addressed Key Question 2a; two studies described in three articles discussed hospice and addressed Key Question 1b; seven studies discussed nursing homes and addressed Key Question 1b.

## Continuity, Coordination of Care, and Transitions

### Study Characteristics

We found 23 studies detailed in 26 articles addressing this target. The 23 studies were published between the years 2000 and 2011 and had sample sizes in the range of 40 to 710 patients with 17 studies (74 percent) between 100 and 300 patients. Of the 23 studies, 12 were randomized clinical trials (RCTs) and 11 were non-RCTs. Of the 11 non-RCTs, seven were before-after studies conducted in the same setting with a different set of patients as the control group. Five studies were conducted in an inpatient setting, four in a home care setting, four in an ambulatory setting, three in nursing homes, one in hospice, one in a rehabilitation unit, and five in mixed settings. Fifteen studies (65 percent) were multicenter studies. One study reported only within-group comparisons and therefore the outcomes are not further analyzed here53 (Table 3, Appendix E, Evidence Table 1). All studies compared the intervention to usual care.

Table 3 Overview of characteristics of studies addressing continuity

Author/Year/refID | Study Design Sample Size | Population (disease, mean age) | Setting(s) | Description of Intervention
Aiken, 2006^56^ | RCT 192 | COPD, CHF 69 | Home care | Home-based case management by nurse case managers, in coordination with patients' existing source of medical care
Badger, 2009^74^ | Non-RCT 437 | Mixed illnesses, no age reported | Nursing home | Gold Standards Framework in Care Homes - Identifying, assessing and treating needs and symptoms, Improving coordination within institution and outside
Bailey, 2005^77^ | Non-RCT 203 | Mixed illnesses 68 | Hospital | Inpatient Comfort Care Program - Staff education and support to identify actively dying patients and implement comfort care order set template
Bakitas, 2009^57^ | RCT 322 | Mixed cancer 65 | Ambulatory | Multicomponent telephone-based intervention- Education, encourage patient activation, self-management, and empowerment
Bookbinder, 2005^53^ | Non-RCT 257 | Mixed illnesses >70 | Hospital, | Palliative Care for Advanced Disease (PCAD) pathway - daily flow sheet, standard orders for symptom control
Brumley, 2003^65^ | Non-RCT 300 | COPD, CHF, cancer 74 | Home care | Home-Based Palliative Care - Care team (physician, nurse, social worker) assesses, coordinates and manages care
Brumley, 2007^66^ | RCT 297 | COPD, CHF, cancer 72 | Home care | As above
Casarett, 2005^54^ | RCT 205 | Mixed illnesses 84 | Nursing home | Structured interview and notification of residents' physicians about residents' preference for hospice care
Cohen, 2010^55^ | Non-RCT 133 | Dialysis patients with poor prognosis 70 | Ambulatory | Intervention to facilitate hospice referral - Renal supportive care teams encouraged care planning, discussed hospice resources, offered general support
Dudgeon, 2008^69^ | Non-RCT 200 | Mixed cancer 66 | Ambulatory, hospital, home care | Palliative care integration project - Implementation of assessment tools, collaborative care plans, symptom management guidelines
Engelhardt, 2006^67^ | RCT 275 | COPD, CHF mixed cancer 70 | Hospital, home care | Advanced illness coordinated care program- 6 sessions with care coordinator who helps with provider communication, care coordination, support
Hughes, 2000^58^ | RCT 188 | Mixed illnesses 70 | Home care | Team-Managed Home-Based Primary Care - care manager, 24-hour contact, prior approval of hospital readmissions, discharge planning
Jordhoy, 2000^78^, 2001^59^, Ringdal 2002^72^, 2001^79,*^ | RCT 434 | Mixed cancer 68 | Home care, ambulatory, palliative medicine unit | Comprehensive palliative care - All in- and outpatient services occurred on Palliative Medicine Unit, Unit staff served as link to community, predefined guidelines, educational programs for community
Luhrs, 2005^75^ | Non-RCT 39 | Mixed illnesses 72 | Hospital | Palliative Care for Advanced Disease (PCAD) pathway - daily flow sheet, standard orders for symptom control
McMillan, 2011^60^ | RCT 709 | Mixed cancer 73 | Hospice | Systematic feedback of assessment to interdisciplinary teams (IDTs) - Standardized assessment followed by two interdisciplinary team (IDT) discussions
Mitchell, 2008^61^ | RCT 159 | Mixed illnesses 65-72 | Ambulatory, hospital | Specialist-general practitioner case conferences: General practitioner phoning in to a routine specialist team meeting
Moore, 2002^62^ | RCT 202 | Lung cancer 67 | Ambulatory | Nurse led followup: Nurse specialists assessed patients monthly or as needed by phone or in clinic
Pantilat, 2010^73^ | RCT 107 | CHF, COPD, mixed cancer, Cirrhosis 76 | Hospital | Hospital-based palliative care consultation: daily during hospitalization, palliative care physician assessed patient, discussed treatment preferences
Rabow, 2004^63^ | Non-RCT 90 | COPD, CHF, cancer 68 | Ambulatory | Comprehensive care team - Primary care physician received palliative care team consultations, patients received care planning, psychosocial support, family caregiver training.
Reymond, 2011^71^ | Non-RCT 299 | Mixed illnesses Not reported | Nursing home | Residential aged end-of-life care pathway - Identifying and training nurse champions, networking facilities with specialty palliative care, educating physicians, development and implementation of end-of-life clinical management care pathway
Woo, 2011^68^ | Non-RCT 169 | Mixed illnesses (majority dementia) 84 | Rehabilitation and convalescent unit | Continuous quality improvement initiative (Plan-do-study-act) - Service reengineering, provision of guidelines, educational material, and interactive sessions to achieve culture change
Temel, 2010^64^ | RCT 151 | Metastatic lung cancer 65 | Ambulatory | Early palliative care integrated with standard oncologic care - Palliative care physician/advance practice nurse consult within 3 months of diagnosis and then monthly; addressed physical and psychosocial symptoms, goals of care, treatment decisionmaking, coordination
v.d Heide, 2010^80^ | Non-RCT 298 | Mixed cancer 64-75 | Hospital, nursing home, home care | Liverpool Care Pathway for the Dying Patient - Structuring care, facilitating audit by standardizing the monitoring of care

Abbreviations: RCT = randomized controlled trial; CHF = chronic health failure; COPD = chronic obstructive pulmonary disease

* Multiple publications on the same study

The populations in these studies were adults with a mean age (by study) between 62 and 84. Most of the studies included patients with mixed illnesses (n=9) or cancer patients only (n=7). Five studies focused on cancer, chronic obstructive pulmonary disease or chronic heart failure patients, one study included dialysis patients, and one included chronic heart failure and chronic obstructive pulmonary disease patients. None of the studies reported anything on disparities (Table 3, Appendix E, Evidence Table 1).

In 20 (87 percent) of studies, the interventions addressed multiple targets of palliative care. All but two included targets of coordination of care or an interdisciplinary team as part of the intervention. The two studies54,55 that did not include one of these targets focused on facilitated referrals to hospices. In 11 studies, the existing staff provided the intervention, in nine studies an external team or consultant provided the intervention, and in three studies a mix of these two provided the intervention. Studies addressed a wide range of interventions and outcomes, and quantitative synthesis was judged not to be appropriate due to this diversity (Table 3, Appendix E, Evidence Tables 2 and 3).

Risk-of-bias (ROB) scores were high for 10 studies, medium for eight, and low for five. Eleven of the studies were non-RCTs, some RCTs did not adequately report the randomization process, and most did not report blinding of outcome assessment (Appendix E, Evidence Table 4).

### Key Question 1 What is the effectiveness of health care and palliative care interventions for improving the quality of palliative care?

#### Key Question 1a Specific Targets

See Figure 1, Framework, column 3, for a listing of targets.

##### Key Points

There was a moderate strength of evidence for improvement in satisfaction, based on six medium-quality studies for patients and four for caregivers, both with consistent results.

###### Patient Quality of Life and Satisfaction

Nine studies evaluated quality of life (QOL) of patients;56-64 eight were RCTs. Only three studies (33 percent) showed a statistically significant improvement in patient QOL with the intervention.57,58,64 Whether or not the instrument used for QOL measurement was specifically designed for that population had no influence on the results. In addition, the sample size was the same in the studies that showed an effect compared to the studies showing no effect. Also, neither the intervention targets nor the setting explained the likelihood of a significant finding (Table 4, Appendix E, Evidence Table 5).

Table 4 Outcomes of studies addressing continuity

Author, Year | Study Design; Sample Size | ROB | Results Statistically Significant Improvement With the Intervention vs. the Control Group
| | | Patient QOL; Caregiver Burden or QOL | Patient Satisfaction; Family Satisfaction | Symptom Control | Health Care Utilization
Aiken, 2006^56^ | RCT 192 | Low | No | | No | No
Badger, 2009^74^ | Non-RCT 437 | High | | | | Yes
Bailey, 2005^77^ | Non-RCT 203 | Medium | | | | No
Bakitas, 2009^57^ | RCT 322 | Medium | Yes | | No | No
Bookbinder, 2005^53^ | Non-RCT 257 | High | | | | No between group significance testing
Brumley, 2003^65^ | Non-RCT 300 | Medium | | No between group significance testing | | Yes
Brumley, 2007^66^ | RCT 297 | Low | | Yes | | Yes
Casarett, 2005^54^ | RCT 205 | Low | | Yes | | Yes (hospice referral)
Cohen, 2010^55^ | Non-RCT 133 | High | | | | No
Dudgeon, 2008^69^ | Non-RCT 200 | High | n/a No | No | No | No
Engelhardt, 2006^67^ | RCT 275 | High | | Yes
Hughes, 2000^58^ | RCT 188 | Medium | Yes; No | No; Yes | | No
Jordhoy, 2000^78^, 2001^59^, Ringdal 2002^72^, 2001^79^ | RCT 434 | High | No | Yes | | No
Luhrs, 2005^75^ | Non-RCT 39 | Medium | | | | No
McMillan, 2011^60^ | RCT 709 | High | No | | No
Mitchell, 2008^61^ | RCT 159 | Low | No No
Moore, 2002^62^ | RCT 202 | Low | No | Yes | | No
Pantilat, 2010^73^ | RCT 107 | High | | | No
Rabow, 2004^63^ | Non-RCT 90 | Medium | No | No | No | No
Reymond, 2011^71^ | Non-RCT 299 | High | | No | | No significance testing
Woo, 2011^68^ | Non-RCT 169 | High | N/A No | Yes | No | Yes
Temel, 2010^64^ | RCT 151 | High | Yes | | Yes (only depression measured) | No for all Yes for patients who died
v.d Heide, 2010^80^ | Non-RCT 298 | High | None of these outcomes measured

Abbreviations: RCT = randomized controlled trial; QOL = Quality of life; COPD = chronic obstructive pulmonary disease; CHF = chronic heart failure; ROB = risk of bias

Seven studies assessed patient satisfaction (every study used a different satisfaction scale).58,62,63,65-68 Four studies were RCTs. One study reported within-group comparison only, and was therefore not included in the analysis.65 Of the other six studies, four (67 percent) showed statistically significant effects for this outcome in favor of the intervention.62,65,67,68 The quality of the studies, the sample size, the settings and the target of intervention did not influence the likelihood of a significant finding (Table 4; Appendix E, Evidence Table 1 though 4).

Three studies measured both patient satisfaction and QOL.58,62,63 Findings for the two outcomes were different for two of the studies (one statistically significant, one not) and the same for only for one study63 (both were not statistically significant) (Table 4, Appendix E, Evidence Table 5).

Five out of seven studies that reported significant improvement in QOL or satisfaction in the intervention group included coordination of care processes in the intervention. On the other hand, only one of four studies not using coordination of care processes showed significant results in one of these outcomes (Table 4, Appendix E, Evidence Table 5).

###### Caregiver Satisfaction, Quality of Life, and Burden

Six studies reported caregiver satisfaction.58,68-71 Four of these studies (67%) showed statistically significant improvement with the intervention,58,68,70 including three RCTs and a non-RCT. The targets of the interventions and the sample size were comparable among the studies. The instruments used to measure satisfaction had no influence on the likelihood of a statistically significant finding. One study with a positive result on satisfaction evaluated grief as well, which showed no difference between the groups (Table 4, Appendix E, Evidence Table 5).72

Only one study reported caregiver QOL.68 This study evaluated QOL with two different instruments and both showed statistically significant improvement with the intervention. Three studies reported caregiver burden;58,61,69 two were RCTs. None of the studies showed a significant difference between the intervention and control group (Table 4, Appendix E, Evidence Table 5).

Among the three studies evaluating at least two of these three outcomes, two had conflicting findings for the different outcomes and one had a similar finding among outcomes; in that study, neither caregiver burden or satisfaction showed a statistically significant improvement with the intervention (Table 4, Appendix E, Evidence Table 5).69

###### Symptoms

Eight studies in the target of continuity, coordination, and transitions assessed patient symptoms;56,57,60,63,64,68,69,73 five were RCTs. None of the studies showed statistically significantly improvement of overall symptoms in the intervention group versus the control group. In five of these eight studies,57,60,63,64,68 a specific symptom showed a statistically significant improvement in the intervention compared to the control group: in three RCTs,57,60,64 there was a statistically significant improvement with the intervention on depression symptoms; one non-RCT reported a statistically significant improvement for dyspnea, and another non-RCT showed a statistically significant improvement for pain. (Table 4, Appendix E, Evidence Table 5).

###### Health Care Utilization (Decreased Admissions or Length of Stay, Increased Hospice Referral)

Sixteen studies reported impact on health care utilization,56-58,62,64-66,68-69,71-72,74-76 characterized by length of stay or different types of admissions; one did not report statistics on the results. Seven of these studies were RCTs. Only five of the 16 studies (31 percent) reported a statistically significant improvement with the intervention compared to the control group (four decreased admissions or length of stay, and one improved hospice referral.54,65,66,68,74 (Table 4, Appendix E, Evidence Table 5).

###### Location of Death

Six studies reported location of death (e.g., whether the patient died at home or in his or her preferred location),54,64,69,74,77-78 three of which were RCTs. In three studies (50 percent), two of which were RCTs, the intervention had a statistically significant impact in the percentage of patients who died at home or in their preferred location.64,74,78 The sample sizes and patient mix were comparable among all studies (Table 4, Appendix E, Evidence Table 5).

###### Specialized Palliative Care Usage

Four studies reported enrollment in hospices, use of hospice services or placing patients on a comfort care plan.54,55,64,75 One RCT, which focused on the outcome of improving hospice referrals in nursing homes, reported significant results in favor of the intervention at 30 days but not at time of death.54 A non-randomized study55 and a RCT64 (of a broader intervention and not powered for this outcome) reported non-significant results, while another very small non-RCT reported significant results in favor of the intervention. (Table 4, Appendix E, Evidence Table 5)75

#### Key Question 1b Specific Settings

##### Key Points

Too few studies to draw conclusions in the hospice or nursing home setting.

One study was conducted in hospice and four included the nursing home setting (Table 4, Appendix E, Evidence Table 5); there were too few studies in these settings to draw conclusions.

An RCT of systematic feedback of standardized assessments and interdisciplinary team discussions in hospices60 found a statistically significant improvement with the intervention in patient depression, but not in patient symptoms or caregiver depression (Table 4, Appendix E, Evidence Table 5).

Three studies evaluated care pathways in nursing homes, and one focused on increasing hospice referrals. A 2010 non-RCT evaluated the Liverpool Care Pathway for the Dying Patient across hospital, nursing home, and home settings; among the 80 nursing home patients included, the intervention did not significantly increase the quality of care measure of do-not-resuscitate orders. A 2009 study of the Gold Standards Framework,74 addressing symptoms, needs, and coordination in 49 nursing homes, found statistically significant reductions in deaths in the nursing home and crisis hospitalizations with the intervention. A multicenter study of a different care pathway in nursing homes found no improvement in bereaved families' satisfaction.71 Finally, Casarett et al.54 conducted an RCT identifying nursing home residents appropriate for hospice care and communicating this information to their physicians. The intervention resulted in statistically significant improvements in hospice enrollment (1 percent for the control group compared to 20 percent for the intervention group, p=0.001) and patient satisfaction, and found statistically significant decreases in hospital utilization (Table 4, Appendix E, Evidence Table 5, Appendix F).

### Key Question 2 What is the evidence for different quality improvement models for improving palliative care?

#### Key Question 2a Different Types of Quality Improvement Interventions

##### Key Points

Six of the nine studies (67%) using patient-centered quality improvement types such as patient/family/caregiver education and promotion of self-management showed a significant improvement with the intervention for the outcomes of patient quality of life or satisfaction, compared to three of nine studies (33%) using provider-centered interventions.

###### Quality Improvement Types

The interventions in the studies for continuity, coordination, and transitions included between one and five quality improvement (quality improvement) types (for details see methods, Table 2); 13 (57 percent) included three or four quality improvement types. Fifteen studies included organizational change; 13 included facilitating relay of clinical data to providers; nine included promotion of self-management or patient/family/caregiver education; nine included provider reminder systems and provider education; and four included training for implementation of quality improvement (Table 4, Appendix E, Evidence Tables 2 and 3).

###### Patient Quality of Life and Satisfaction

Of the nine studies56-59,63-64,66-68 identified that used patient-centered quality improvement types such as patient/family/caregiver education and promotion of self-management, six (67 percent) showed a significant effect in favor of the intervention on satisfaction or QOL. One of the three non-significant studies reported that some of the control group received specialized palliative care as well.59 Of the ten studies56,59-63,66-68 using provider-centered interventions (such as provider reminder systems, facilitated relay of clinical data to providers, or provider education), only three (30 percent) had a significant effect on QOL or satisfaction in favor of the intervention. All three studies that did show an effect of the intervention also included patient-centered quality improvement types (Table 4, Appendix E, Evidence Table 5).

###### Caregiver Satisfaction, Quality of Life, and Burden

Of the three studies using patient and family-centered quality improvement types (such as patient/ family/ caregiver education and promotion of self-management), all showed a statistically significant improvement in caregiver satisfaction with the intervention.58,68,72 The three studies showing no effect on any of these three outcomes were studies that included only provider-centered quality improvement types or organizational change, and did not include patient- and family-centered quality improvement types61 69 (Table 4, Appendix E, Evidence Table 5).

###### Symptoms

The eight studies for the targets of continuity, coordination, and transitions which evaluated overall symptoms as an outcome, which showed no statistically significant impact from the intervention, most commonly included the following quality improvement types: facilitated relay of clinical data to providers (seven studies), organizational change (six studies), provider reminder systems (five studies), and patient/family/caregiver education (five studies) (Table 4, Appendix E, Evidence Table 5).

###### Health Care Utilization (Decreased Admissions or Length of Stay, Increased Hospice Referral)

Of the 16 studies reporting statistics which evaluated this outcome, seven used the quality improvement type provider education. Of these seven studies, four (57 percent)65,66,68,74 found a statistically significant improvement in health care utilization (decreased admissions or length of stay) in the intervention compared to the control group. Also, two of four studies (50 percent) using provider reminder systems68,74 in the intervention and two of three studies (66 percent) using quality improvement training to implement the intervention68,74 reported a significant improvement with the intervention. Only three of the nine studies using the quality improvement type facilitated relay of data to providers54,68,74 were associated with significant results. Studies using patient-centered quality improvement strategies like patient/family/caregiver education and promotion of self-management reported a statistically significant improvement in utilization outcomes with the intervention in only three of the eight (38 percent) of the studies.65,66,68 Three of the ten studies (30 percent)65,66,74 which used some version of organizational change found a statistically significant improvement (Table 4, Appendix E, Evidence Table 5).

###### Specialized Palliative Care Usage and Location of Death

We did not find any association between quality improvement strategies and study findings for the outcome of specialized palliative care usage or location of death.

For all outcomes, when including only the results of the high- and medium-quality studies (excluding the low-quality studies), the overall findings were consistent.

#### Key Question 2b Different Models in Palliative Care: Integrative Compared With Consultative

This Key Question was not analyzed for this target.

### Grading of the Evidence

Risk of bias was generally low to medium for RCTs and medium to high for non-RCTs. All outcomes were direct except health care utilization, which was graded as indirect because it is considered a surrogate outcome in palliative care, and has not been shown to be directly related to patient-centered outcomes such as satisfaction. Precision was not applicable due to diversity of outcomes measurement tools, and study diversity was high for all outcomes, with a wide variety of different types of interventions. Study results did not generally differ between the RCTs and non-RCTs or between high-and medium- and low-quality studies. For QOL, most studies were RCTs with medium risk of bias and evidence was inconsistent. For patient satisfaction, evidence was consistent for both RCTs and non-RCTs. For caregiver burden, evidence was consistent for the two RCTs; for caregiver satisfaction, evidence was consistent for both the RCTs and the non-RCTs. For symptoms, evidence was consistent for the five RCTs and consistent for the three non-RCTs. For health care utilization, evidence was consistent for both the RCTs and non-RCTs. Strength of evidence was low across all outcomes except for satisfaction, where it was moderate. (Table 5).

Table 5 Evidence grading for continuity (KQ1a and KQ2a)

Number of Studies; Subjects | Domains Pertaining to Strength of Evidence, by Key Outcomes | | | | Strength of Evidence That the Intervention Improved Outcomes Compared With the Control Group
| Risk of bias | Consistency | Directness for outcome | Precision; Study diversity
Patient QOL | | | | | Low SOE
8; 2562 | RCT/medium | Inconsistent | Direct | not applicable; high | Low
1; 90 | Non-RCT/medium | Not applicable | Direct | not applicable; not applicable | Low
Patient Satisfaction | | | | | Moderate SOE
4; 962 | RCT/medium | Consistent | Direct | not applicable; high | Moderate
3; 559 | Non-RCT / high | Consistent | Direct | not applicable; high | Low
Caregiver Burden | | | | | Low SOE
2; 448 | RCT/ medium | Consistent | Direct | not applicable; high | Low
1; 200 | Non-RCT / high | Not applicable | Direct | not applicable; not applicable | Low
Caregiver Satisfaction | | | | | Low SOE
3; 472 | RCT/medium | Consistent | Direct | not applicable; high | Low
3; 668 | Non-RCT / high | Consistent | Direct | not applicable; high | Low
Symptoms | | | | | Low SOE
5; 1481 | RCT/medium | Consistent (no effect) | Direct | not applicable; high | Low
3; 459 | Non-RCT / high | Consistent (no effect) | Direct | not applicable; high | Low
Health Care Utilization * | | | | | Low SOE
7; 1641 | RCT/medium | Inconsistent | Indirect for surrogate outcome | not applicable; high | Low
6; 1634 | Non-RCT /high | Inconsistent | Indirect for surrogate outcome | not applicable; high | Low

* admissions, length of stay, interventions

Abbreviations: KQ=Key Question; SOE = strength of evidence; RCT= randomized controlled trial; QOL = quality of life

## Pain

### Study Characteristics

The 21 included studies described in 23 articles spanning the years 2000 to 2011. The median sample size was 105 patients (range: 43-187). Sixteen studies examined mixed cancer populations, while one study examined gynecologic cancers,81 two studies examined lung cancer only,82,83 and two focused on patients with severe dementia.84,85 Sixteen studies were conducted in an ambulatory setting, two were conducted in nursing homes,84,85 two in home care,86,87 and one in a hospital.88 Mean age of study participants ranged from 52 years to approximately 86.5 years of age, with a median of 59.7 years of age. Median followup time following the initiation of the intervention was eight weeks (range: 2-24 weeks), excluding one study89 which performed followup to the patient's death. Fourteen out of the 21 studies were conducted in the United States (67 percent), two studies were conducted in Canada,84,86 one in Australia,88 one in Italy,89 and three in the Netherlands (Table 6, Appendix E, Evidence Tables 1, 6 and 7).87,90

Table 6 Characteristics of studies targeting pain

Author/Year | Study Design | Sample Size^*^ | Setting | Intervention
Anderson 2004^106^ | RCT | 97 | Ambulatory | Patient education consisting of race- and gender-tailored video, followed by a nurse-led meeting and a followup call.
Aubin, 2006^86^ | Non-RCT | 80 | Home care | One-time educational intervention
Borneman, 2008^83^ | Non-RCT | 46 | Ambulatory | Four-part educational intervention
Borneman, 2010^92^ | Non-RCT | 157 | Ambulatory | Four-part educational intervention
Dalton, 2004^104^ | RCT | 127 | Ambulatory | Profile-tailored CBT treatment program
Du Pen, 2000 91 | RCT | 105 | Ambulatory | Provider focused education intervention on implementing a previously tested algorithm for cancer pain management
Fuchs-Lacelle, 2008^84^ | RCT | 173 | Nursing Home | Nurse-led systematic pain assessment
Given, 2002^95^ | RCT | 113 | Ambulatory | Ten-part nurse-implemented pain and fatigue management educational intervention
Keefe, 2005^102^ | RCT | 78 | Home care | Three-session nurse-led partner-guided pain management intervention
Kovach 2006 85 | RCT | 114 | Nursing Home | Serial trial intervention, a protocol of assessing needs of people with dementia
Lovell, 2010^88^ | RCT | 185 | Hospital | Pain management educational intervention utilizing a booklet and a video
Marinangeli, 2004^89^ | RCT | 92 | Ambulatory | Use of strong opioids as first line therapy
Miaskowski, 2004^93^ and Miaskowski 2007^94,**^ | RCT | 174 167 | Ambulatory | Six-week nurse-led psychoeducational intervention
Oldenmenger 2011 90 | RCT | 72 | Ambulatory | Pain consult plus specialized nurse-conducted patient education program (PEP).
Oliver, 2001^99^ Kalauokalani, 2007^107,**^ | RCT | 67 | Ambulatory | One-time individualized education and coaching session
Syrjala, 2008^96^ | RCT | 78 | Ambulatory | Patient training in cancer pain management using integrated print and video materials
van der Peet, 2004^87^ | RCT | 120 | Home care | Three-visit nurse-led pain education program
Ward, 2000^81^ | RCT | 43 | Ambulatory | Nurse-led individually tailored information
Ward, 2008^100^ | RCT | 176 | Ambulatory | Single one-on-one psychoeducational session based on the representation approach to patient education
Wells, 2003^98^ | RCT | 64 | Ambulatory | Pain education with a hotline and pain education with provider-initiated followup telephone calls
Wilkie, 2010^82^ | RCT | 151 | Ambulatory | Individualized pain coaching on self monitoring and reporting

Abbreviations: RCT = randomized controlled trial; CBT = cognitive behavioral therapy

* All studies conducted in populations of cancer patients, besides Fuchs-Lacelle and Kovach, which focused on advanced dementia patients.

** Articles are listed together when more than one article provided results on the same study.

Out of the 21 studies, 18 (86 percent) were RCTs. Nineteen randomized at the patient level, one study randomized by institution block,91 and one study randomized by nursing home unit level.84 The three remaining studies used non-equivalent control groups.83,86,92 Six studies were conducted in a single setting, and 15 were conducted in multiple settings, ranging from two to 21 sites.83,92 All compared the intervention to usual care. Patient pain was the target in all 21 (100 percent) of the studies (Table 6, Appendix E, Evidence Tables 1, 6 and 7).

Five of the studies (24 percent) used facilitated relay of data to providers as a quality improvement element.83,84,87,89,93,94 Five studies (24 percent) used provider education as a component of the intervention,83,85,86,91,95 while 18 studies (86 percent) employed patient, family, and/or caregiver education. Five of these studies utilized print and video materials to enhance the educational intervention.86,87,93,96,97,98 One study used print material alone,81 and one study used video material alone.82

Risk-of-bias scores were high for five studies, medium for six, and low for ten. Three of the studies were non-RCTs, some RCTs did not adequately report the randomization process, and many did not report blinding of outcome assessment (Table 6, Appendix E, Evidence Table 8).

### Key Question 1 What is the effectiveness of health care and palliative care interventions for improving the quality of palliative care?

#### Key Question 1a Specific Targets

See Figure 1, Framework, column 3, for a listing of targets.

##### Key Points

There was a moderate strength of evidence for outcome of improvement in pain, based on 21 medium-quality studies (18 RCTs) with inconsistent results; 18 of the studies were patient/caregiver education/self-management.

###### Pain

All 21 included studies assessed pain as an outcome. Fourteen out of 21 studies (67 percent) used the Brief Pain Inventory (BPI) as the pain measurement tool. One study83 used the Quality of Life Scale/Cancer Patient Tool, one study95 used the Symptom Experience Scale, one study89 used a visual analog scale, and one82 used the McGill Pain Questionnaire. One other study used treatment data to determine patient pain experience.92 Of the two studies focusing on dementia, one study84 used the Pain Assessment Checklist for Seniors with Limited Ability to Communicate, and the other used the Discomfort-Dementia of the Alzheimer's Type. (Table 7, Appendix E, Evidence Table 9).85 Additional issues with outcome reporting of these studies that precluded quantitative synthesis included inconsistent reporting of the BPI, which raised concerns for selective outcome reporting (e.g., only nine of the 14 studies reported average pain). Only five of the studies reported confidence intervals or effect sizes, and reported time to outcome also varied. (Table 8)

Table 7 Outcomes for studies targeting pain

Author/Year | Pain | QOL | BPI^*^ | BPI Measure Reported^*^
Anderson 2004^106^ | NS | NS | Y | Worst pain, pain interference
Aubin, 2006^86^ | S | | Y | Average pain, worst pain
Borneman, 2008^83^ | NS | | N
Borneman, 2010^92^ | NS | | N
Dalton, 2004^104^ | NS | NS | Y | Worst, least, average, pain now, pain right now, pain Interference with walking, sleep, relationships, activity, composite severity score, composite interference score
Du Pen, 2000 91 | S | | Y | Aggregate score of worst pain and usual pain
Fuchs-Lacelle, 2008^84^ | NS | | N
Given, 2002^95^ | NS | | N
Keefe, 2005^102^ | NS | NS | Y | Worst pain, usual pain
Kovach 2006 85 | S | | N
Lovell, 2010^88^ | S | NS | Y | Average pain, worst pain, pain interference
Marinangeli, 2004^89^ | S | NS | N
Miaskowski, 2004^93^ and Miaskowski 2007^94^ | S | NS (except for one subscale) | Y | 93 Least pain, average pain, worst pain 94 Total interference score, individual scores for activity, mood, walking, work, relations with others, sleep, enjoyment of life, sexual activity
Oldenmenger 2011^90^ | S | | Y | Current pain, average pain, worst pain in past 24 hours; pain interference
Oliver, 2001^99^ Kalauokalani, 2007^107^ | S | | Y | Average pain
Syrjala, 2008^96^ | S | | Y | Usual pain, worst pain, interference with function (overall)
van der Peet, 2004^87^ | S | NS | Y | Present pain
Ward, 2000^81^ | NS | NS | Y | Worst pain, pain interference composite score
Ward, 2008^100^ | NS | NS | Y | BPI severity composite score, pain interference composite score
Wells, 2003^98^ | NS | | Y | Worst pain, average pain, pain interference, pain relief
Wilkie, 2010^82^ | NS | | N

Abbreviations: S = significant; NS = not significant; BPI = Brief Pain Inventory

* Whether or not BPI was the measurement tool used for the pain outcome, and which aspect of the BPI measure was reported. These were assessed to determine whether the measurement tools used, and the aspects reported, were homogeneous enough across studies for quantitative synthesis of the literature. BPI was used in many studies, but different aspects were reported across studies, making quantitative synthesis impractical.

Table 8 BPI results for studies targeting pain

Author/year | N | Pain | Quality Of Life | Brief Pain Inventory (BPI) | BPI Measure Reported | Reporting Issues for Studies Using BPI With Positive Findings
Anderson 2004 | 97 | NS | NS | Y | Worst pain, pain interference | 2 week and 1 month post-intervention assessment, no confidence intervals (CIs)
Aubin, 2006 | 80 | S | | Y | Average pain, worst pain | 2 week and 4 week post-intervention assessment
Borneman, 2008 | 46 | NS
Borneman, 2010 | 157 | NS
Dalton, 2004 | 127 | NS | NS | Y | Worst, least, average, pain now, pain Interference with walking, sleep, relationships, activity, composite severity score, composite interference score | Assessment immediately post-intervention, 1month, and 6 months; no CIs
Du Pen, 2000 | 105 | S | | Y | Aggregate score of worst pain and average pain | 1 month, between 2.5 and 4 month post-intervention assessment; no CIs
Fuchs-Lacelle, 2008 | 173 | NS
Given, 2002 | 113 | NS
Keefe, 2005 | 78 | NS | NS | Y | Worst pain, average pain | Assessment approximately one week after intervention; standard deviations, no CIs
Kovach 2006 | 114 | S
Lovell, 2010 | 185 | S | NS | Y | Average pain, worst pain, pain interference | Unclear whether reporting 2 week or 4 week measurement in results
Marinangeli, 2004 | 92 | S | NS
Miaskowski, 2004 and Miaskowski 2007* | 174 | S | NS (except for one subscale) | Y | Least pain, average pain, worst pain Total interference score, individual scores for activity, mood, walking, work, relations with others, sleep, enjoyment of life, sexual activity | No CIs
Oldenmenger 2011^90^ | 72 | S | | Y | Current pain, average pain, worst pain in past 24 hours; pain interference | 2 week, 1 month and 2 month assessment following intervention; No CIs
Oliver, 2001 and Kalauokalani, 2007* | 67 | S | | Y | Average pain | 2 week post-intervention assessment
Syrjala, 2008 | 78 | S | | Y | Average pain, worst pain, interference with function (overall) | 1 month, 3 month, and 6 month assessment post-intervention; No CIs
van der Peet, 2004 | 120 | S | NS | Y | Present pain | 4 week assessment post-intervention, no CIs
Ward, 2000 | 43 | NS | NS | Y | Worst pain, pain interference composite score | 1 and 2 month post intervention followup, no data on BPI
Ward, 2008 | 176 | NS | NS | Y | BPI severity composite score, pain interference composite score | 1 month and 2 month assessment post-intervention
Wells, 2003 | 64 | NS | | Y | Worst pain, average pain, pain interference, pain relief | 1 month post-intervention followup, continued monthly followup for six months; no CIs
Wilkie, 2010 | 151 | NS

Ten of the 21 studies showed statistically significant improvement with the interventions on pain scores compared to the control group. This was similar for small studies (<100) and larger studies (100-200, 5 of 11 (45%) showed significant improvement). Types of reported pain scores measured by the BPI included worst pain, average pain, usual pain, current pain, least pain, pain relief, and pain interference. Of those studies using the BPI to measure pain outcomes, two studies88,93 demonstrated significant improvement with the interventions on both average and worst pain scores, two studies87,99 showed significant differences by group on scores for current pain, three studies found significant effects for usual or average pain.86,91,96 and one study found significant effects for average and current pain.90 Two studies, which used visual analog scales to measure pain rather than the BPI, found significant pain improvements in the intervention group relative to controls. (Table 7, Appendix E, Evidence Table 9).85,89

Among interventions with significant impact on patient pain outcomes, number of encounters ranged from one86,88 to six.93 Among those interventions shown to have no significant impact on pain outcomes, number of encounters ranged from one100 to 10.^84^ Of the seven effective interventions that targeted patients and caregivers, four (57 percent) were conducted in ambulatory settings,88,90,96,99 two in home care,86,87 and one in a hospital.93,94 Only two studies out of the eight showing a significant improvement with the intervention were conducted at a single site89,90 (Table 7, Appendix E, Evidence Table 9).

###### Quality of Life

Nine of the 21 (43 percent) studies measured QOL as an outcome. Of these nine studies, only one93,94 found any improvement with the intervention on QOL. Moreover, this study only found an improvement on a single sub-scale of a quality of life measure. There was no consistency among these eight studies in the measurement of QOL; every study used a different instrument. Even in the cases where the intervention demonstrated significant positive outcomes for pain, there were no commensurate significant gains in QOL (Table 7, Appendix E, Evidence Table 9).

#### Key Question 1b Specific Settings

No studies were in the hospice setting. Two studies targeted pain in nursing homes. One multicenter RCT of 21 nursing units evaluated routine observational pain assessment checklist for patients with dementia;84 the study found a statistically significant improvement with the intervention for pain medication use. The study did not report the impact of the intervention on patients' pain. A multicenter RCT in 14 nursing homes that looked at implementation a protocol for assessing discomfort found a significant improvement with the intervention both on nurses' assessments and on patient discomfort (Table 7, Appendix E, Evidence Table 9, Appendix F).

### Key Question 2 What is the evidence for different quality improvement models for improving palliative care?

#### Key Question 2a Different Types of Quality Improvement Interventions

##### Key Points

Eighteen of the 21 studies targeting pain used patient/family/caregiver education and/or promotion of self-management as quality improvement types.

###### Patient, Family, and/or Caregiver Education

All studies that used patient, family, and/or caregiver education also used promotion of patient/caregiver self-management. One study82 used a patient and caregiver reminder system as a component of the intervention. One study83 used organizational change in their intervention. None of the studies used financial incentives, regulations or policy to affect pain outcomes (Table 7, Appendix E, Evidence Table 9).

Among those 18 studies that used patient, family, and caregiver education and promotion of self-management, 12 of the studies included multiple contacts with the patient.82,87,90,92,93-95,97,98,101,102-104 The number of followup contacts among these studies ranged from one brief 10-minute followup96 or followup phone call97 to 10 individual contacts over the course of 20 weeks95 (Table 7, Appendix E, Evidence Table 9).

The majority (86 percent) of the studies examined patient-directed educational interventions. Three studies focused on provider-level interventions only. One of these studies89 focused on the use of strong opioids as first-line therapy in cancer pain management as the intervention under study, one91 employed a provider education program about using an algorithm to improve cancer pain management, and one85 used a serial trial intervention--a protocol for assessing the needs of people with dementia (Table 7, Appendix E, Evidence Table 9). The nine studies demonstrating a significant positive impact of interventions on patient pain outcomes varied in scope, intensity, and target of intervention. Moreover, studies were diverse in the respect that interventions were delivered at different points in patients' illness trajectories, and study participants varied in health status at the time of the interventions. Three of these studies focused on provider behavior. One study91 implemented a provider training program to improve provider adherence to a previously tested cancer pain management algorithm. The other provider-focused study used a systems-change approach (testing the efficacy of using strong opioids as first-line therapy in cancer pain management, relative to the WHO Analgesic Ladder89), and the other used a serial-trial intervention to help nurses and staff assess unmet needs of patients85 The other seven studies demonstrating improvements in pain management focused on patient and caregiver education and promotion of self-management (Table 7, Appendix E, Evidence Table 9).

Eight studies focused on patient, family, and caregiver education as well as promotion of self-management.86-88,90,93,96,97,105 In addition to patient education and promotion of self-management, two of these studies also included facilitated relay of clinical data to providers,87,93 and one also included pain consultation.90 One study included provider education in addition to patient education and promotion of self-management.86 Of the three positive studies not including patient and caregiver education, two included provider education alone,85,91 and the other consisted of facilitated relay of clinical data to providers (Table 7, Appendix E, Evidence Table 9).89

#### Key Question 2b Different Models in Palliative Care: Integrative Compared With Consultative

This Key Question was not analyzed for this target.

### Grading of the Evidence

Risk of bias was low for RCTs and medium for non-RCTs. Precision was not applicable because study results could not be quantitatively combined; outcomes were reported differently and effect sizes were not reported consistently. Study diversity was moderate for both outcomes; although almost all populations were mixed cancer and interventions focused on patient education, the timing, nature, and scope of the interventions was relatively diverse. Because of their patient-centeredness, both outcomes were direct: pain interventions should impact directly on pain outcomes, and pain is also an element of many QOL measurement tools and directly affects quality of life. For pain, a direct outcome, most studies were RCTs and evidence was inconsistent in the direction of improvement, and for QOL, all studies were RCTs and evidence was consistent with no effect. Strength of evidence was moderate for pain, given directness and relatively consistent results, and low for quality of life given consistent findings of no effect. (Table 9).

Table 9 Grading of the evidence on studies addressing pain (KQ1a and KQ2a)

Number of Studies; Subjects | Domains Pertaining to Strength of Evidence, by Key Outcomes | | | | Strength of Evidence That the Intervention Improved Outcomes Compared With the Control Group
Number of Studies; Subjects | Risk of bias: | Consistency | Directness for outcome | Precision; Study diversity | Strength of Evidence That the Intervention Improved Outcomes Compared With the Control Group
Pain | | | | | Moderate SOE
18; 2176 | RCT/Medium | Consistent | Direct | Not applicable; Medium | Moderate
3; 313 | Non-RCT/Medium | Inconsistent | Direct | Not applicable: Medium | Low
Quality of Life | | | | | Low SOE
7; 1259 | RCT/Medium | Consistent (no effect) | Direct | Not applicable; Medium | Low

## Distress

### Key Points

There was a low strength of evidence for outcome of distress, based on 7 high- and medium-quality RCTs with consistent results finding no improvement with the intervention.

### Study Characteristics

We found seven studies that met our inclusion criteria for interventions in patients with serious and advanced illness and focused on the target of distress. The seven studies were published between 2005–2010 and had sample sizes ranging from 28-1,134 patients. All seven studies were RCTs. Of the seven studies, four were based in ambulatory settings, two were home-based and one was a combination of home and ambulatory settings. Five studies were multicenter and two were single-center trials. Six studies were in cancer populations and one study focused on patients eligible for lung transplant. All compared the intervention to usual care, except for one intervention that measured three different methods of distress screening. Because of the small number of interventions included in this section, study characteristics are described for each individual study listed below. (Table 10, Appendix E, Evidence Tables 1, 10 and 11).

Table 10 Study characteristics of studies addressing distress

Author/Year | Study Design | Sample Size | Setting | Intervention
Aranda, 2006^111^ | RCT | 106 patients | Ambulatory | Coaching on self-care, stress reduction and communication
Blumenthal, 2006^109^ | RCT | 328 patients | Home-based | Telephone-based coping skills
Carlson, 2010^108^ | RCT | 1134 patients | Ambulatory | Psychological screen with personalized feedback
Hudson, 2005^114^ | RCT | 106 patients | Home-based | Guidebook on caregiver role and self-care
Porter, 2010^112^ | RCT | 233 patients | Ambulatory | Telephone-based coping skills, education and support
Steel, 2007^113^ | RCT | 28 patients | Ambulatory | Patient identification of distress symptoms
Walsh, 2007^110^ | RCT | 271 patients | Home-based/Ambulatory | Needs assessment, advice and support

Abbreviation: RCT = randomized controlled trial

Studies addressing distress were less diverse in design than studies addressing continuity and pain. All but one study received risk of bias assessment of low. The one study assessed as having a medium risk of bias differed from the others in that it was unclear how the study handled sequence generation and allocation concealment. (For details on how each individual study was assessed see Appendix E, Evidence Table 12).

### Key Question 1 What is the effectiveness of health care and palliative care interventions for improving the quality of palliative care?

#### Key Question 1a Specific Targets

See Figure 1, Framework, column 3, for a listing of targets.

Only two of the seven studies demonstrated a significantly significant difference between the intervention and control groups. One RCT108 evaluated 1,134 outpatients with lung (549 patients) or breast cancer randomized to one of three online methods of distress screening--a minimal screening group assessed using a distress thermometer only, a full screening intervention group using the problem checklist and a cancer-oriented psychological screen for anxiety and depression with a personalized feedback report, and a triage intervention group using and the full screen and personalized phone triage with an offer of referral to relevant resources. In the patients with advanced disease (the lung cancer group), the study108 reported no change in distress among patients in the distress thermometer-only group or full screening group. They did find that, after the intervention, the triage intervention group had a significant improvement in the primary outcome of distress and fewer patients over the distress cutoff (30.7 percent), compared to the minimal screening group at 51.3 percent (p=0.001). There were no significant improvements in depression or anxiety (Table 11, Appendix E. Evidence Table 13).

Table 11 Outcomes for studies targeting distress

Author/Year | Outcomes
Author/Year | Distress | Depression | Anxiety
Aranda, 2006^111^ | NS
Blumenthal, 2006^109^ | S | S | NS
Carlson, 2010^108^ | S | NS | NS
Hudson, 2005^114^ | NS | NS
Porter, 2010^112^ | NS
Steel, 2007^113^ | NS | NS
Walsh, 2007^110^ | NS

Abbreviations: S= significant; NS = not significant

Another RCT109 randomized 328 lung transplant candidates to receive telephone-based coping skills training. For 12 weeks, they received weekly supportive counseling and training in cognitive-behavioral coping skills and education on stress and health, using a standardized program and trained therapists. For the primary outcomes of depression and distress, the study found that both depression and distress reduction in the intervention group was greater than the control group (11.1 to 9.8 vs. 12.6 to 8.8, p=0.003 and 45.2 to 43.2 vs. 48.1 to 39.7, p=0.035, respectively). There were no significant differences in several measures of QOL (Table 11, Appendix E. Evidence Table 13).

The five negative studies were all patient-oriented trials in cancer populations. One study110 enrolled 271 caregivers of patients dying of cancer at home, providing them six visits by advisors to assess needs and provide advice and support. Another111 provided coaching on self-care, stress reduction, and communication strategies to 106 patients. A physician received summary results for assessment and conducted a telephone followup one week later. Porter112 enrolled 233 lung cancer patients to receive caregiver-assisted coping skills training. The study randomized patient and caregiver groups to receive either 14 telephone-based, caregiver-assisted coping skills training sessions or 14 telephone-based, caregiver-assisted education/support sessions. In a small study, Steel113 randomized 28 patients to receive an individually tailored psychosocial intervention. Patients chose from a list of concerns that were most distressing (symptoms, psychological, and end of life issues) and received strategies to treat each problem. The final study114 enrolled 106 caregivers to evaluate a psycho-educational intervention for family members. Nurses delivered the intervention during two home visits and a phone call. Caregivers received a guidebook and audiotape on caregiver role, self-care and care of the dying (Table 11, Appendix E. Evidence Table 13).

#### Key Question 1b Specific Settings

No studies addressing this target applied to this Key Question.

### Key Question 2 What is the evidence for different quality improvement models for improving palliative care?

#### Key Question 2a Different Types of Quality Improvement Interventions

##### Key Points

Six of the seven studies for distress were patient education and self-management-oriented interventions. Only one of these studies found a significant improvement with the intervention.

#### Key Question 2b Different Models in Palliative Care: Integrative Compared With Consultative

This Key Question was not analyzed for this target.

### Grading of the Evidence

For distress, all studies were RCTs, and for both the outcomes of distress and depression, the risk of bias was medium, evidence was inconsistent, the outcome was direct, and precision was not applicable. Study diversity was high for distress and moderate for depression, and strength of evidence was low. (Table 12).

Table 12 Grading of evidence for distress (KQ1a and KQ2a)

Number of Studies; Subjects | Domains Pertaining to Strength of Evidence, by Key Outcomes | | | | Strength of Evidence That the Intervention Improved Outcomes Compared With The Control Group
Number of Studies; Subjects | Risk of bias | Consistency | Directness for outcome | Precision; Diversity of comparisons | Strength of Evidence That the Intervention Improved Outcomes Compared With The Control Group
Distress | | | | | Low SOE
7; 2206 | RCT/Medium | Consistent (no effect) | Direct | Not applicable; Moderate | Low
Depression | | | | | Low SOE
4; 1596 | RCT/Medium | Consistent (no effect) | Direct | Not applicable; Moderate | Low

## Communication and Decisionmaking

### Study Characteristics

The sample sizes of the 20 studies were in the range of 63-2,891 patients with 57 percent between 150-900 patients and a mean sample size of 526. In total, 13 out of the 20 studies were conducted in an intensive care unit (ICU) with one of these in a neonatal ICU.115 The remaining seven studies were conducted in non-ICU settings: one nursing home, two ambulatory and four hospital. Of all the identified 20 studies, 50 percent were carried out in multiple centers and 50 percent in single centers; nine of the 20 studies were RCTs comparing the results of patients receiving an intervention to those receiving usual care, and the remaining 11 studies were non-RCTs. Of the 11 non-RCTs, seven were pre-post prospective studies conducted in the same setting with different sets of patients (Table 13, Appendix E, Evidence Table 1).

Table 13 Characteristics of studies addressing communication and decisionmaking

Author, Year | Study Design | Sample Size | Setting | Centers | Mean Age | Disease Population | Family Meeting | Physician-Patient Communication | Palliative Care Team | Ethics Consultation
Ahrens, 2003^127^ | Non-RCT | 151 | ICU | single | Adult | Mixed illnesses | Yes
Campbell, 2003^119^ | Non-RCT | 81 | ICU | Single | Adult | Mixed illnesses | | | Yes
Clayton, 2007^122^ | RCT | 174 | Ambulatory | Multi-center | 65 | Mixed Cancer | | Yes
Cowan, 2003^45^ | Non-RCT | 873 | ICU | Multi-center | 61 | Mixed illnesses | Yes
Gade, 2008^117^ | RCT | 517 | Hospital | Multi-center | 73.6 | Mixed illnesses | | | Yes
Hanks, 2002^118^ | RCT | 261 | Hospital | Multi-center | 68.4 | Mixed illnesses | | | Yes
Jacobsen, 2011^125^ | Non-RCT | 899 | Hospital | Single | 62.9 | Mixed illnesses
Kaufer, 2008^129^ | Non-RCT | 88 | ICU | Single | Adult | Mixed illnesses | Yes
Laurette, 2007^132^ | RCT | 63 | ICU | Multi-center | 68-74 | Mixed illnesses | Yes
Lilly, 2000^126^ | Non-RCT | 530 | ICU | Single | 58-60 | Mixed illnesses | Yes
Lilly, 2003^124^ | Non-RCT | 2891 | ICU | Single | 59 | Mixed illnesses | Yes
Molloy, 2000^131^ | RCT | 1133 | Nursing Homes | Multi-center | 83.1 | Mixed illnesses
Mosenthal, 2008^128^ | Non-RCT | 367 | ICU | Single | 40 | Trauma | Yes
Muir, 2010^48^ | Non-RCT | 480 | ICU | Multi-center | 53-56 | Mixed illnesses | Yes
Norton, 2007^130^ | Non-RCT | 191 | ICU | Single | 66.1 | Mixed illnesses | | | Yes
Penticuff, 2005^134^ | Non-RCT | 154 | NICU | Multi-center | VLBW | Pediatric | Yes
Sampson, 2011^133^ | RCT | 32 | Hospital | single | 87 | Advanced Dementia | | | Yes
Schneiderman, 2000^121^ | RCT | 70 | ICU | Single | 45.9-52.4 | Mixed illnesses | | | | Yes
Schneiderman, 2003^120^ | RCT | 546 | ICU | Multi-center | 67.5 | Mixed illnesses | | | | Yes
Tulsky, 2011^123^ | RCT | 264 | Ambulatory | Multi-center | 61 | Mixed Cancer | | Yes

Abbreviations: VLBW = very low birth weights; ICU = intensive care unit; NICU = neonatal intensive care unit

All but one of the populations in these studies consisted of adults with a mean age between 40 and 87. Most of the studies included patients with mixed illnesses (n=15) while others included mixed cancer patients only (n=2), advanced dementia patients only (n=1), trauma patients only (n=1) and pediatric patients with very low birth-weight (n=1) (Table 13, Appendix E, Evidence Table 1). All studies compared the intervention to usual care, except for one study of a question prompt list where both groups were seen by palliative care.

The types of interventions were categorized into four groups (Table 13):

1. Family meetings with one or more of the patient's usual health providers, usually a physician, nurse, and/or social worker. These family meetings were information sharing and/or decisionmaking meetings with patients and families to improve communication, particularly around end-of-life issues. Eleven studies used this type of intervention.
2. Interdisciplinary palliative care teams. Four studies116-119 used this type of intervention, including a palliative care physician and nurse, hospital social worker and/or chaplain that met with the patient/family and usual care clinical team to address issues such as patient symptoms, diagnosis, prognosis, and goals of care. One of these interventions also focused on advance care planning.116
3. Ethics consultations. Two studies120,121 examined the impact of ethics consultations, defined as the use of specialized help in identifying, analyzing, and resolving ethical problems that arise in the care of the patient to resolve conflicts about life-sustaining interventions.
4. Physician-patient communication. Two studies were in this category. One study evaluated the use of a question prompt list for patients with advanced cancer receiving palliative care consultation to assist patients to ask questions about end-of-life issues and improve patient-physician communication around prognosis/end-of-life care issues.122 For the other study,123 physicians in the intervention group used a CD-ROM training program on communication skills that was tailored with examples from their own clinic visits.

The target of intervention for 13 studies (65 percent) was the interdisciplinary team.45,48,118-121,124-130 Three studies (16 percent) addressed psychosocial and spiritual support in palliative care,117,120,122 while two RCTs focused on ethical issues in palliative care.120 121 Fourteen studies (70 percent) targeted advanced care planning and decisionmaking on goals of care in end-of-life care45,48,115,119,124-133 (Table 13, Appendix E, Evidence Tables 14 and 15).

All the studies (100 percent) on interventions for communication used patient, family and/or caregiver education as a quality improvement element. Eighty-five percent of these studies included promotion of self-management as an element of quality improvement.45,48,115,117,118,120-122,124-126,128-133 Eleven studies (55 percent) used facilitated relay of clinical data to providers as a component of intervention,45,48,117-120,122,126,127,129,130 and only one used provider reminder system for quality improvement.119 Other quality improvement elements used in these studies include provider education (50 percent),48,115,119-121,123,125,127,131,132 coaching and collaborative skills training to implement quality improvement (40 percent),48,119-121,125,127,129,131 audit and feedback (25 percent),45,48,117,129,130 organizational change (10 percent),117,119 and patient and family reminders (5 percent).118 None of these studies used financial incentives, regulations or policy as a quality improvement element for interventions to improve communication and decisionmaking in palliative care (Table 13, Appendix E, Evidence Tables 14 and 15).

Risk-of-bias scores were low for seven studies and medium for the remainder. In general, risk of bias was medium for the RCTs (Appendix E, Evidence Table 16).

### Key Question 1 What is the effectiveness of health care and palliative care interventions for improving the quality of palliative care?

#### Key Question 1a Specific Targets

See Figure 1, Framework, column 3, for a listing of targets.

##### Key Points

There was a moderate strength of evidence for the indirect outcome of health care utilization, based on 6 medium-quality RCTs and 9 RCTs with consistent results (11 of 15 studies showed improvement with the intervention).

###### Patient and Family Satisfaction

Eight studies evaluated patient satisfaction.45,115,117,118,122,123,129,131 Five of these eight studies were RCTs and three were non-RCTs. Only one RCT (14 percent) showed a statistically significant improvement on patient satisfaction;117 it used interdisciplinary palliative care service as an intervention to address patient and family needs for information and decisionmaking on goals of care. The studies with no significant improvement on patient satisfaction mainly used standardized family meetings with a physician, nurse, or social worker (not a palliative care team) as an intervention to improve communication and decisionmaking. (Table 14, Appendix E, Evidence Table 17).

Table 14 Outcomes of studies addressing communication and decisionmaking

Author, Year | Study Design | Sample Size | Risk of Bias | Patient Satisfaction | Family Satisfaction | Health Care Utilization | Quality of Life | Symptoms | Integrative v. Consultative
Ahrens, 2003^127^ | Non-RCT | 151 | Low | | | Significant | | | Combined
Campbell, 2003^119^ | Non-RCT | 81 | Medium | | | Significant | | | Consultative
Clayton, 2007^122^ | RCT | 174 | Low | Not Significant | | | | | Integrative
Cowan, 2003^45^ | Non-RCT | 873 | Medium | Not Significant | | Significant | | | Consultative
Gade, 2008^117^ | RCT | 517 | Low | Significant | | Significant | Not Significant | Not Significant | Consultative
Hanks, 2002^118^ | RCT | 261 | Low | Not Significant | | Not Significant | Not Significant | Not Significant | Consultative
Jacobsen, 2011^125^ | Non-RCT | 899 | Medium | | | Significant | | | Integrative
Kaufer, 2008^129^ | Non-RCT | 88 | Medium | Not Significant | Significant | | | Not Significant | Consultative
Laurette, 2007^132^ | RCT | 63 | Low | | | Not Significant | | Significant | Combined
Lilly, 2000^126^ | Non-RCT | 530 | Medium | | | Significant | | | Integrative
Lilly, 2003^124^ | Non-RCT | 2891 | Medium | | | Significant | | | Integrative
Molloy, 2000^131^ | RCT | 1133 | Medium | Not Significant | Not Significant | Significant | | | Integrative
Mosenthal, 2008^128^ | Non-RCT | 367 | Medium | | | Significant | | | Combined
Muir, 2010^48^ | Non-RCT | 480 | Medium | | | Not Significant | | | Integrative
Norton, 2007^130^ | Non-RCT | 191 | Medium | | | Not Significant | | | Consultative
Penticuff, 2005^134^ | Non-RCT | 154 | Medium | Not Significant | | | | | Integrative
Sampson, 2011^133^ | RCT | 32 | Medium | | Not Significant | | | | Combined
Schneiderman, 2000^121^ | RCT | 70 | Medium | | | Significant | | | Consultative
Schneiderman, 2003^120^ | RCT | 546 | Low | | | Significant | | | Consultative
Tulsky, 2011^123^ | RCT | 264 | Low | Not significant | | | | | Integrative
| | | | Patient Satisfaction | Family Satisfaction | Health care utilization | Quality of Life | Symptoms
Number of studies addressing outcome | | | | 8 | 3 | 15 | 2 | 4
Number with statistically significant impact | | | | 1 | 1 | 11 | 0 | 1

Three studies assessed family satisfaction; two RCTs131,133 including one131 with a large sample size (n= 1,133) showed no significant improvement in family satisfaction, and a non-RCT with a small sample size (n= 88) showed significant improvement with the intervention in family satisfaction129 (Table 14, Appendix E, Evidence Table 17).

###### Health Care Utilization

We categorized studies that evaluated ICU length of stay, hospital length of stay, and/or use of advance directives, as evaluations of health care utilization. Six RCTs of medium quality evaluated health care utilization in terminally ill patients.117,118,120,121,131,132 Four of these six studies (66.7 percent) showed a statistically significant improvement with the intervention compared to the control group (e.g., reduced ICU length of stay).117,120,121,131 Nine non-RCTs evaluated health care utilization. Seven of these nine non-RCTs (77.7 percent) showed a statistically significant improvement with the intervention.45,119,124-128 The sample size, intervention type, targets of the intervention, or setting, did not explain the difference in the four studies that showed non-significant results (Table 14, Appendix E, Evidence Table 17).

###### Quality of Life

Two good-quality RCTs assessed the QOL of patients.117,118 They both showed no significant improvement on QOL of patients in the intervention and usual care groups. These two studies independently used the same type of intervention (palliative care consultation) among different sample populations in similar settings to improve provider-patient and family communication and decisionmaking in palliative care (Table 14, Appendix E, Evidence Table 17).

###### Symptom Control

Four studies evaluated symptom control of patients: three of these four were good-quality RCTs,117,118,132 and the last was a medium-quality non-RCT.129 Only one of these four studies (25 percent), an RCT,132 showed a statistically significant improvement in symptom control. It also had the smallest sample size (n= 63) of all the studies (Table 14, Appendix E, Evidence Table 17).

#### Key Question 1b Specific Settings

We found no studies in hospice, but did find one study in the nursing home setting for this target. In a 2000 study, Molloy et al131 conducted an RCT educating providers, patients, and families about advance directives, measuring end-of-life outcomes. Although there was no significant impact of the intervention on satisfaction, there was an impact on the rate of hospitalizations and hospital length of stay (2.61 vs. 5.86 days, p=0.01) (Table 14, Appendix E, Evidence Table 17, Appendix F).

### Key Question 2 What is the evidence for different quality improvement models for improving palliative care?

#### Key Question 2a Different Types of Quality Improvement Interventions

This Key Question was not analyzed for this target.

#### Key Question 2b Different Models in Palliative Care: Integrative Compared With Consultative

##### Key Points

Four of the eight (50 percent) integrative studies had a significant improvement with the intervention, compared to six of the eight (75 percent) consultative studies.

Eight interventions were integrative and four of the eight (50 percent) had a significant improvement in at least one key outcome in the intervention compared to the control group. In contrast, eight interventions were consultative in nature and six of the eight (75 percent) had a significant improvement with the intervention in at least one key outcome. The interventions from four studies were combined (included both integrative and consultative models). Interventions were highly diverse and the number of studies in each classification group was small (Table 14, Appendix E, Evidence Table 17).

### Grading of the Evidence

All outcomes were direct except health care utilization, and precision was not applicable because of heterogenous outcomes and outcome reporting. For patient satisfaction, both RCTs and non-RCTs had medium risk of bias; evidence was consistent (no effect), and strength of evidence was low. For family satisfaction, evidence was inconsistent, and strength of evidence was low. For health care utilization, risk of bias was medium for both RCTs and non-RCTs, evidence was consistent for impact of improvement in outcomes with the intervention, and strength of evidence was moderate: overall 11 out of the 15 studies (73 percent) showed an improvement with the intervention for this outcome. For QOL, risk of bias was low for two non-RCTs, evidence was consistent (no improvement with the intervention in either study), and strength of evidence was low. For symptom control, risk of bias was low for three RCTs and medium for non-RCTs; evidence was consistent for the RCTs (no improvement with the intervention) and strength of evidence was low. Strength of evidence was the same across RCTs and non-RCTs (Table 15).

Table 15 Evidence grading for studies addressing communication and decisionmaking (KQ1a and KQ2b)

Number of Studies; Subjects | Domains Pertaining to Strength of Evidence, by Key Outcomes | | | | Strength of Evidence That the Intervention Improved Outcomes Compared With the Control Group
Number of Studies; Subjects | Risk of bias: | Consistency | Directness for outcome | Precision | Strength of Evidence That the Intervention Improved Outcomes Compared With the Control Group
Patient Satisfaction | | | | | Low SOE
5; 2349 | RCT/medium | Consistent (no effect) | Direct | Not applicable | Low
3;1115 | Non-RCT/medium | Consistent (no effect) | Direct | Not applicable | Low
Family satisfaction | | | | | Low SOE
2; 1165 | RCT/medium | Inconsistent | Direct | Not applicable | Low
1;88 | Non-RCT/medium | Not applicable | Direct | Not applicable | Insufficient
Health care utilization * | | | | | Moderate SOE
6; 2590 | RCT/medium | Consistent | Indirect | Not applicable | Moderate
9; 6463 | Non-RCT/medium | Consistent | Indirect | Not applicable | Moderate
QOL | | | | | Low SOE
2;778 | RCT/low | Consistent (no effect) | Direct | Not applicable | Low
0 | Non-RCT/not applicable | Not applicable | Direct | Not applicable | Not applicable
Symptom control | | | | | Low SOE
3; 841 | RCT/low | Consistent (no effect) | Direct | Not applicable | Low
1; 88 | Non-RCT/medium | Not applicable | Direct | Not applicable | Insufficient

* Intensive care unit or hospital length of stay, advance directive completion

## Interventions With Multiple or Other Targets

### Key Points

Low strength of evidence was found across outcomes, including improvement of quality of life and symptom relief, for interventions with multiple or other targets.

### Study Characteristics

This section includes studies that met the inclusion criteria but mainly focused on multiple targets or, in a few cases, addressed a target outside the four key targets (e.g., timeliness of treatment). Given the diversity of studies, this section is organized differently than previous sections—by type of quality improvement intervention. These studies mostly fit a narrower definition of quality improvement and address the evidence specifically for these quality improvement types. The sample sizes of the 19 studies described in 21 articles were in the range of 53–822 patients (and one study addressing 644 clinical sites).135 Ten studies were in the ambulatory setting, two in an ICU, two in the home setting, two in a nursing home, one in hospice, one in multiple sites, and one in another setting (palliative day-care center). Eleven were RCTs (Table 16, Appendix E, Evidence Tables 1, 18 and 19). Because this group of studies was so diverse, characteristics of each study are described separately rather than summarized for the entire section.

Table 16 Characteristics of studies addressing multiple or other targets

Targets | Author/Year | Study Design | Sample Size | Setting | Intervention
Facilitated relay of clinical data | Detmar, 2002^143^ | RCT | 214 | Ambulatory | Preconsultation QOL survey
Facilitated relay of clinical data | Mills, 2009^142^ | RCT | 115 | Ambulatory | Patient-held QOL diary
Facilitated relay of clinical data | Rosenbloom, 2007^144^ | RCT | 213 | Ambulatory | QOL survey with interpretive assistance
Facilitated relay of clinical data | Taenzer, 2000^145^ | RCT | 53 | Ambulatory | Preconsultation QOL survey
Facilitated relay of clinical data | Velikova, 2004^140^, Velikova, 2010^141^ | RCT | 286 | Ambulatory | Preconsultation QOL survey
Audit and feedback | Campion, 2011^135^ | Non-RCT | 644 sites | Ambulatory | Performance measurement program
Audit and feedback | Jacobs, 2002^146^ | Non-RCT | 194 | Hospital | Evaluative feedback to individual physicians
Provider education | Keay, 2003^138^ | Non-RCT | 176 | Nursing home | Half-day physician education with audit and feedback
Patient/caregiver education and self-management | Sherwood, 2005^147^ | RCT | 124 | Ambulatory | Cognitive-behavioral intervention for symptoms
Patient/caregiver education and self-management | Sikorskii, 2007^148^ | RCT | 435 | Home | Nurse-assisted symptom management
Patient/caregiver education and self-management | McMillan, 2007^136^ 2006^137^ | RCT | 709 | Hospice | Training family caregivers to assist with symptom management
Patient/caregiver education and self-management | Meyers, 2011^151^ | RCT | 476 | Ambulatory/home | Problem-solving with patient-caregiver dyads
Patient/caregiver education and self-management | Rummans, 2006^149^ | RCT | 115 | Ambulatory | Structured multidisciplinary QOL intervention
Organizational change | Holt, 2010^152^ | Non-RCT | 292 | Ambulatory | Clinic providing more accessible, efficient palliative radiotherapy
Multiple quality improvement types | Curtis, 2008^153^ | Non-RCT | 590 | ICU | Education, local champions, feedback, system support
Multiple quality improvement types | Curtis, 2011^154^ | RCT | 822 | ICU | Same as above
Multiple quality improvement types | Hanson, 2005^139^ | Non-RCT | 458 | Nursing home | Plan-do-study-act with education, training, feedback, leadership
Other (new clinical services) | Goodwin, 2003^155^ | Non-RCT | 173 | Other | Palliative day care
Other (new clinical services) | Grande, 2000^156^ | RCT | 229 | Home | Hospital at home for palliative care

Risk of bias was low for four studies, medium for 14 studies, and high for one. In general, RCTs had low or medium risk of bias. Most studies did not report blinding, and some RCTs did not report details of randomization or allocation (Appendix E, Evidence Table 20).

### Key Question 1 What is the effectiveness of health care and palliative care interventions for improving the quality of palliative care?

#### Key Question 1a Specific Targets

See Figure 1, Framework, column 3, for a listing of targets.

This Key Question was not analyzed for these studies which focused on multiple or other targets.

#### Key Question 1b Specific Settings

We found one study (described in two publications) in the hospice setting and two studies in nursing homes.

For hospice, one RCT136,137 randomized caregivers to the Creativity, Optimism, Planning, Expert (COPE) information intervention, compared to standard hospice care. The study found significant improvements with the intervention on caregiver QOL (estimate 0.096, p=0.04) and task burden (estimate 0.01, p=0.04), as well as patient distress (estimate 0.101, p=0.009) (Table 17, Appendix E, Evidence Table 21).

Table 17 Outcomes of studies addressing multiple and other targets^*^

Target | Author, Year | Study Design | Sample Size | QOL | Satisfaction | Quality of Care | Patient symptoms | Caregiver QOL | Caregiver psychosocial support | Hospice Use | Health Care Use | Psychosocial Support | Symptoms
Facilitated relay of clinical data | Detmar, 2002^143^ | RCT | 214 | NS | NS
Facilitated relay of clinical data | Mills, 2009^142^ | RCT | 115 | NS | NS
Facilitated relay of clinical data | Rosenbloom, 2007^144^ | RCT | 213 | NS | NS
Facilitated relay of clinical data | Taenzer, 2000^145^ | RCT | 53 | | NS | NS
Facilitated relay of clinical data | Velikova, 2004^140^, Velikova, 2010^141^ | RCT | 286 | S | NS
Audit and feedback | Campion, 2011^135^ | Non-RCT | 644 sites | | | S (10/15 measures)
Audit and feedback | Jacobs, 2002^146^ | Non-RCT | 194 | | | NS (9/10 items)
Provider education | Keay, 2003^138^ | Non-RCT | 176 | | | S
Patient/caregiver education and self-management | Sherwood, 2005^147^ | RCT | 124 | | | | S
Patient/caregiver education and self-management | Sikorskii, 2007^148^ | RCT | 435 | | | | NS
Patient/caregiver education and self-management | McMillan, 2007^136^ 2006^137^ | RCT | 709 | | | | NS pain, S distress | S | S
Patient/caregiver education and self-management | Meyers, 2011^151^ | RCT | 476 | NS | | | | S
Patient/caregiver education and self-management | Rummans, 2006^149^ | RCT | 115 | S | | | NS
Organizational change | Holt, 2010^152^ | Non-RCT | 292 | | | S
Multiple quality improvement types | Non-RCT | 590 | NS | NS | | | | | | S | | | Non-RCT
Multiple quality improvement types | RCT | 822 | NS | NS | | | | | | NS | | | RCT
Multiple quality improvement types | Non-RCT | 458 | | | S | | | | S | | | | Non-RCT
Other (new clinical services) | Non-RCT | 173 | NS (9/10 items) | | | | | | | | | | Non-RCT
Other (new clinical services) | RCT | 229 | | | | | | | | NS | NS | NS (6/7 items) | RCT

* empty cells = not reported

Abbreviations: RCT = randomized controlled trial; NS = not significant; S = significant; QOL = quality of life

For nursing homes, one study addressed provider education and one included multiple quality improvement types. Keay138 conducted a half-day physician education multicenter RCT that provided quality improvement improvement suggestions to the medical directors. The study found statistically significant improvements in symptom control during dying for quality indicators related to terminal care in nursing homes (19 to 45 percent, p<0.001). Hanson et al139 conducted a non-RCT including multiple quality improvement types in nine nursing homes. Post-intervention, there was a significant increase in hospice enrollment from 4 to 6.8 percent (p=0.01), and in the use of pain assessments (18 to 60 percent, p<0.001) and advance care planning discussions (4 to 17 percent, p<0.001). Use of pain interventions did not change (Table 17, Appendix E, Evidence Table 21, Appendix F).

### Key Question 2 What is the evidence for different quality improvement models for improving palliative care?

#### Key Question 2a Different Types of Quality Improvement Interventions

##### Physician/Other Provider Reminder Systems

We did not find any additional studies focusing on this quality improvement type other than those summarized in the target sections above (Table 17, Appendix E, Evidence Table 21).

##### Facilitated Relay of Clinical Data to Providers

We found six publications on five studies meeting our inclusion criteria focusing on relay of clinical information for quality improvement. The studies were published between 2000-2011 and had patient sample sizes ranging from 53-286. All five studies were RCTs conducted in ambulatory settings; four were single-centers treating in-patients with metastatic cancer, and one was multicenter, treating lung cancer patients (Table 17, Appendix E, Evidence Table 21).

Only one of the five studies demonstrated a significant improvement with the intervention on QOL or satisfaction. Velikova, 2004^140^ conducted a three-arm RCT, randomizing patients to complete a touch-screen health-related QOL survey that provided feedback to physicians, to complete the QOL survey without feedback to physicians, or to not complete a survey. After three visits post-randomization, a higher number of symptoms were mentioned during the clinical encounter in the intervention group (where patients completed the survey that provided feedback to the physician) than in the other two control groups (Estimate Effect: 4.51; p=0.03). The intervention improved QOL when compared to the control group (Estimate Effect: 8.01, p=0.006). In an study reporting analysis of secondary outcomes of evaluations of care141, patients in the intervention group reported significantly higher ratings for communication (p=0.03) but not for two other subscales or for satisfaction with care (Table 17, Appendix E, Evidence Table 21).

Mills, 2009^142^ studied the use of a structured patient-held QOL diary at home weekly for 16 weeks; patients were encouraged to share it with their health care providers. There were no significant differences between the groups for the primary QOL measure or for satisfaction. However, there were some significantly worse secondary QOL outcomes in the intervention group compared to the control group. Most patients did not give feedback to their providers (Table 17, Appendix E, Evidence Table 21).

Detmar143 used a QOL questionnaire among patients undergoing palliative chemotherapy at three consecutive visits to determine the effect on patient-physician communication. Ten physicians were enrolled in a randomized, crossover study to receive a graphic summary of responses to the questionnaire prior to consultation. After three visits, patients in the intervention group reported significantly greater communication on QOL issues with their physicians than those in the control (Mean: 4.7 vs. 3.7; p=0.01), but there was no significant differences in secondary outcomes of QOL or patient satisfaction (Table 17, Appendix E, Evidence Table 21).

Two studies144,145 found no differences in any reported outcomes between their intervention and control groups. Rosenbloom, 2007^144^ evaluated the improvement with QOL screening with physician interpretive assistance on QOL outcomes and satisfaction among patients with metastatic cancer. This three-arm study randomized 213 patients to complete a QOL survey with followup interview and discussion, complete a QOL survey without followup or receive usual care. After followup at three and six months, the study saw no significant improvement in QOL and satisfaction among the groups Taenzer, 2000,^145^ evaluated the effect of a computerized screening on physician behavior and patient satisfaction. The study randomized 53 patients with lung cancer undergoing treatment to complete a computerized QOL survey prior to consultation that clinical staff reviewed. The study saw no significant differences in patient satisfaction or physician charting between the two groups (Table 17, Appendix E, Evidence Table 21).

##### Audit and Feedback

We identified two studies focusing on audit and feedback. Campion et al.135 reported the evaluation of end-of-life outcome measures in the American Society for Clinical Oncology (ASCO) Quality Oncology Practice Initiative (QOPI) in 644 clinical sites. This voluntary initiative includes a twice-yearly data reporting and analysis cycle and offers participating practices extensive, site-specific, and benchmarking reports that describe the continuum of care. Sites reporting in multiple periods vs. sites reporting only in Fall 2010 had statistically significantly better performance on multiple quality measures, including all four measures for pain management, two of three dyspnea measures, and four of seven measures on hospice and palliative care discussions and referrals; there was no difference in chemotherapy use at the end of life. Jacobs et al.146 conducted a non-RCT where physicians received three biannual palliative care reports on patients where death was likely, including patient/family satisfaction and reported symptom relief and timeliness of advance directive discussions. The study found no difference in quality of care on 10 items evaluated through chart reviews. Physicians may not have reviewed their reports, and feedback may have been too delayed (between 3 and 9 months after care) (Table 17, Appendix E, Evidence Table 21).

##### Provider Education

We identified one non-RCT addressing only this quality improvement type that met the inclusion criteria. Keay138 conducted a half-day education seminar for five nursing homes and provided quality improvement suggestions targeting medical directors and physicians with the majority of patients. A before-after evaluation found statically significant improvements in symptom control during dying for quality indicators for terminal care for nursing homes (19 to 45 percent, p<0.001).

##### Patient/Caregiver Education and Self-Management

We identified six publications on five studies that met inclusion criteria and focused on this quality improvement type but addressed multiple targets and symptoms. Four of the studies136,147,148 focused on reducing symptom severity, one study149 focused on maintaining QOL for patients with advanced cancer. These studies were published between 2005 and 2007 and had sample sizes ranging between 115 and 437. The patient populations in these studies had a cancer diagnosis. All studies were randomized, controlled trials. Two of the studies147,149 were in ambulatory settings, one148 in the home setting, one136 in hospice, and one in multiple settings. Two150 were a multicenter studies while the others were single-center. All studies had a consultative approach (Table 17, Appendix E, Evidence Table 21).

One study147 randomized 124 patients with stage III or stage IV cancer receiving chemotherapy to either standard of care or standard of care plus a cognitive behavioral intervention targeted to decrease severity of symptoms. Experienced oncology nurses delivered five contacts over an 8-week time period aimed at teaching problem-solving techniques to reduce symptom severity. The nurses contacted the patients in person for the first and last sessions, and held the second, third and fourth sessions via telephone. They held the sessions at two-week intervals. The study assessed symptom severity and depressive effect at baseline, 10 weeks, and 20 weeks. The study used The Center for Epidemiologic Studies-Depression Scale to measure depressive symptoms. Patients rated the severity of their symptoms using a 0-10 scale, with 0 representing symptom not present, and 10 representing as severe as it could possibly be. Patients in the intervention group had a mean symptom severity score of 19.1 at 10 weeks (SD=13.1) versus 27.7 (SD=18.9) for the control group. At 20 weeks patients in the intervention group had a mean symptom severity score of 22.1 (SD=15.2) versus 28.2 (SD=19.6) in the control group. Participating in the intervention proved a predictor of lower symptom severity at 20 weeks (p=0.02). The top two reasons for attrition were death (43 percent, N=17) and advancing disease (33 percent, n=13) (Table 17, Appendix E, Evidence Table 21).

The second study148 randomized 437 patients with cancer undergoing chemotherapy to either nurse-assisted symptom management (NASM) or automated telephone symptom management (ATSM). The study compared the impact of a six-contact, 8-week ATSM intervention delivered through an automated system with a NASM intervention (which had previously been found to improve outcomes compared to standard care) delivered by experienced cancer nurses. The study looked at reducing the severity of 17 common symptoms experienced by patients receiving chemotherapy. The study148 assessed severity of 17 symptoms scored by patients using a 0-10 scale (where 0 was no symptom and 10 was the worst severity possible at baseline), at each of the six intervention contacts and at 10 weeks. The study set a threshold at below four or four and higher. It used a Rasch analysis for the data collected at each of the six intervention contacts. The study found no significant differences between the NASM and the ATSM groups post intervention. This study noted a difference in symptom severity between lung and non-lung cancer patients and suggests this as an area for further study (Table 17, Appendix E, Evidence Table 21).

The third study136,137 randomized caregivers of hospice patients to the Creativity, Optimism, Planning, Expert (COPE) information intervention with three home visits and two interim calls to assist with symptom management, compared to standard hospice care. For the primary outcomes, which were caregiver outcomes,137 the study found an impact on caregiver QOL (estimate 0.096, p=0.04) and task burden (estimate 0.01, p=0.04), as well as the burden of patient symptoms. For patient symptoms,136 the study found no impact on dyspnea or pain, but did find an impact on distress (estimate 0.101, p=0.009) (Table 17, Appendix E, Evidence Table 21). The fourth study also used the COPE intervention for patient-caregiver dyads for advanced cancer patients participating in clinical trials, over three educational sessions. The study found statistically significant improvements in caregiver (p=0.02), but not patient, quality of life, but neither patients nor caregivers showed any change in problem-solving skills.151

The fifth study149 randomized 115 advanced cancer patients to either eight structured multidisciplinary sessions or to standard of care. The eight structured sessions lasted for 90 minutes each and addressed the domains of QOL, including cognitive, physical, emotional, spiritual and social functioning. The participants in the intervention group received a manual reviewing material covered in the eight sessions. The study used the Spitzer QOL Uniscale for the primary outcome measure, overall QOL, and the Linear Analog Scale of Assessment of QOL for 12 secondary outcome measures. QOL was assessed at baseline, week four, week eight and week 27. The end of week four marked the end of the intervention in the study. While the results showed a significant difference between intervention and control groups for the primary outcome measure, overall QOL, at the week-four comparison (P=0.047), the results did not show any significant difference between the groups at weeks eight and 27. There was no significant difference found between the control group and intervention group in regards to secondary outcome measures except for spiritual wellbeing (p=0.003) at week four. Additional secondary outcome measures were assessed using the Symptom Distress Scale, Profile of Mood States-Short Form, and the Functional Assessment of Chronic Illness Therapy-Spiritual Well-Being, but none were significant in this study. Of note, this study cost $2,000 for each participant, and recruitment was low: although the participants were all enrolled in radiation therapy and coming to the center daily for treatment, of 418 potential study participants asked to join the study, only 115 enrolled (Table 17, Appendix E, Evidence Table 21).

In summary, four of the five studies of interventions focusing on patient and caregiver education for multiple patient symptoms or QOL had statistically significant findings for at least one key outcome, although one was significant only at one of three time points (Table 17, Appendix E, Evidence Table 21).

##### Organizational Change

We identified one study focusing on organizational change. Holt152 conducted a before-after study of a rapid-response clinic for patients referred for palliative radiotherapy to reduce wait times and have patients seen same-day if possible. They found a statistically significant increase in single-fraction treatment (which is guideline-recommended care) (65 vs. 42 percent, p-0.002), and a statistically significant reduction in time-to-treatment (<24 hours) (74 vs. 27 percent, p<0.001) but found no improvement in waiting times for consultation (Table 17, Appendix E, Evidence Table 21).

##### Financial Incentives, Regulation, and Policy

We did not identify any additional studies for this quality improvement type outside of continuity of care (Table 17, Appendix E, Evidence Table 21).

##### Multiple Quality Improvement Types

We identified three studies that focused on multiple quality improvement types and multiple targets; two studies evaluated the same intervention, one in a non-RCT and the second in a multicenter RCT. Curtis et al.153,154 conducted the Integrating Palliative Care in the ICU study. The study included the quality improvement types clinician education, local champions, academic detailing, feedback to clinicians, and system support, in an integrative intervention with no consultative component. The non-RCT of the intervention found no significant impact on family-completed Quality of Dying and Death or satisfaction153 However, the median length of stay in the ICU was significantly lower in the intervention group compared to the control group (3.85 vs. 3.06, p=0.01). In the multicenter RCT in 12 hospitals, there were no significant differences in any of these outcomes (Table 17, Appendix E, Evidence Table 21).154

Hanson et al.139 conducted a quality improvement non-RCT over a six month period that included multiple quality improvement types in nine nursing homes. The intervention used a plan-do-study-act structure with feedback of performance data at three time points. The quality improvement types studied included recruitment and training of palliative care leadership in each facility, in-depth education and technical assistance meetings for team members, as well as educational sessions for nursing staff. Post-intervention, there was a significant increase in hospice enrollment from 4 to 6.8 percent (p=0.01), and in the use of pain assessments (18 to 60 percent, p<0.001) and advance care planning discussions (4 to 17 percent, p<0.001); use of pain interventions did not change. The nursing homes were relatively diverse, and all volunteered to participate in this study (Table 17, Appendix E, Evidence Table 21).

##### Other

In this category, we identified two studies evaluating new clinical services in palliative care and addressing multiple targets. Goodwin et al.155 found no significant impact on QOL in 173 United Kingdom patients at a palliative daycare center who received a variety of social, recreational, and therapeutic activities for five hours, one day a week, compared to usual palliative care. The needed sample size was not reached in this study and the outcome measures may not have effectively matched the goals of the intervention. Grande et al.156 conducted a single-center RCT published in 2000 of hospital at home for palliative care; the intervention had an impact on only one of seven symptoms and no impact on psychosocial symptoms and support or the percentage who spent time at home in the last two weeks of life (Table 17, Appendix E, Evidence Table 21).

#### Key Question 2b Different Models in Palliative Care: Integrative Compared With Consultative

This Key Question was not analyzed for this target.

### Grading of the Evidence

Study diversity was high amongst these studies, and due to diversity of outcomes, precision was not applicable. All outcomes were direct, except quality of care (since this is not a directly patient-centered outcome), all had medium risk of bias for both RCTs and non-RCTs, and all had inconsistent data where applicable. For the outcome of QOL, there were six RCTs and two non-RCTs. For satisfaction, there were five RCTs and one non-RCT. For quality of care, there was one RCT and two non-RCTs. For patient symptoms, there were five RCTs and one non-RCT. For psychosocial support, there were two non-RCTs (Table 18). Strength of evidence was low overall, and the same for RCTs and non-RCTs

Table 18 Grading of studies in multiple or other targets (KQ2a)

Number of Studies; Subjects | Domains Pertaining to Strength of Evidence | | | | Strength of Evidence That the Intervention Improved Outcomes Compared With the Control Group
Number of Studies; Subjects | Risk of bias: | Consistency | Directness for outcome | Precision; Diversity of comparisons | Strength of Evidence That the Intervention Improved Outcomes Compared With the Control Group
Quality of Life | | | | | Low SOE
7; 1300 | RCT/medium | Inconsistent | Direct | Not applicable; High | Low
2; 763 | Non-RCT/medium | Inconsistent | Direct | Not applicable; High | Low
Satisfaction | | | | | Low SOE
5; 881 | RCT/medium | Inconsistent | Direct | Not applicable; High | Low
1; 590 | Non-RCT/medium | Not applicable | Direct | Not applicable | Low
Quality of Care | | | | | Low SOE
1; 53 | RCT/medium | Not applicable | Indirect | Not applicable | Low
3; >486^*^ | Non-RCT/medium | Inconsistent | Indirect | Not applicable; High | Low
Patient Symptoms | | | | | Low SOE
5; 1612 | RCT/medium | Inconsistent | Direct | Not applicable; High | Low
1; 176 | Non-RCT/medium | Not applicable | Direct | Not applicable | Low
Psychosocial Support | | | | | Low SOE
2; 938 | Non-RCT/medium | Inconsistent | Direct | Not applicable; High | Low

* One study did not report # of patients—conducted in 644 sites