# References

1 Atkins D, Chang S, Gartlehner G, et al. (2010). Assessing the Applicability of Studies When Comparing Medical Interventions.
2 Chang VT, Hwang SS, Kasimis B. (2002). Longitudinal documentation of cancer pain management outcomes: a pilot study at a VA medical center. J Pain Symptom Manage.
3 World Health Organization. WHO Pain Ladder.
4 Johnson VM, Teno JM, Bourbonniere M, et al. (2005). Palliative care needs of cancer patients in U.S. nursing homes. J Palliat Med.
5 Gattellari M, Voigt KJ, Butow PN, et al. (2002). When the treatment goal is not cure: are cancer patients equipped to make informed decisions?. J Clin Oncol.
6 Kirshen AJ, Roff SL. (2011). Defining palliative care competencies in Canadian geriatric medicine subspecialty training. J Am Geriatr Soc.
7 Shojania KG, Ranji SR, Shaw LK, et al. (2004). Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies (Vol. 2: Diabetes Care).
8 Lorenz K, Lynn J, Morton SC, et al. (2004). End-of-life care and outcomes. Evid Rep Technol Assess (Summ).
9 Lorenz KA, Lynn J, Dy SM, et al. (2008). Evidence for improving palliative care at the end of life: a systematic review. Ann Intern Med.
10 Higginson IJ, Finlay I, Goodwin DM, et al. (2002). Do hospital-based palliative teams improve care for patients or families at the end of life?. J Pain Symptom Manage.
11 Zimmermann C, Riechelmann R, Krzyzanowska M, et al. (2008). Effectiveness of specialized palliative care: a systematic review. JAMA.
12 VanderWalde A. (2011). Clinical ethics case report: questionable capacity and the guidance of living wills. J Clin Ethics.
13 Levi BH, Heverley SR, Green MJ. (2011). Accuracy of a decision aid for advance care planning: simulated end-of-life decision making. J Clin Ethics.
14 Higginson IJ, Evans CJ. (2010). What is the evidence that palliative care teams improve outcomes for cancer patients and their families?. Cancer J.
15 Gysels M, Higginson IJ. (2004). Improving Supportive and Palliative Care for Adults With Cancer. Research Evidence Manual.
16 Blackford J, Street A. (2011). Is an advance care planning model feasible in community palliative care? A multi-site action research approach. J Adv Nurs.
17 Kroenke K, Zhong X, Theobald D, et al. (2010). Somatic symptoms in patients with cancer experiencing pain or depression: prevalence, disability, and health care use. Arch Intern Med.
18 Schenker Y, Smith AK, Arnold RM, et al. (2011). “Her Husband Doesn't Speak Much English”: Conducting a Family Meeting with an Interpreter. J Palliat Med.
19 Gutgsell T, Walsh D, Zhukovsky DS, et al. (2003). A prospective study of the pathophysiology and clinical characteristics of pain in a palliative medicine population. Am J Hosp Palliat Care.
20 Prommer E. (2011). Role of codeine in palliative care. J Opioid Manag.
21 Deandrea S, Montanari M, Moja L, et al. (2008). Prevalence of undertreatment in cancer pain. A review of published literature. Ann Oncol.
22 Turillazzi E, Fineschi V. (2011). Advance directives in therapeutic intervention: a review of the Italian bioethical and juridical debate. Med Sci Law.
23 Allard P, Maunsell E, Labbe J, et al. (2001). Educational interventions to improve cancer pain control: a systematic review. J Palliat Med.
24 Bennett MI, Bagnall AM, Jose Closs S. (2009). How effective are patient-based educational interventions in the management of cancer pain? Systematic review and meta-analysis. Pain.
25 Goldberg GR, Morrison RS. (2007). Pain management in hospitalized cancer patients: a systematic review. J Clin Oncol.
26 Brink-Huis A, van Achterberg T, Schoonhoven L. (2008). Pain management: a review of organisation models with integrated processes for the management of pain in adult cancer patients. J Clin Nurs.
27 Cummings GG, Armijo Olivo S, Biondo PD, et al. (2011). Effectiveness of Knowledge Translation Interventions to Improve Cancer Pain Management. J Pain Symptom Manage.
28 Holland JC, Alici Y. (2010). Management of distress in cancer patients. J Support Oncol.
29 Hudson PL, Remedios C, Thomas K. (2010). A systematic review of psychosocial interventions for family carers of palliative care patients. BMC Palliat Care.
30 Preyde M, Synnott E. (2009). Psychosocial intervention for adults with cancer: a meta-analysis. J Evid Based Soc Work.
31 Seitz DC, Besier T, Goldbeck L. (2009). Psychosocial interventions for adolescent cancer patients: a systematic review of the literature (Structured abstract). Psycho-Oncology.
32 Akechi T, Okuyama T, Onishi J, et al. (2008). Psychotherapy for Depression Among Incurable Cancer Patients. Cochrane Database of Systematic Reviews: Reviews.
33 Walling A, Lorenz KA, Dy SM, et al. (2008). Evidence-based recommendations for information and care planning in cancer care. J Clin Oncol.
34 Scheunemann LP, McDevitt M, Carson SS, et al. (2011). Randomized, controlled trials of interventions to improve communication in intensive care: a systematic review. Chest.
35 National Hospice and Palliative Care Organization (NHPCO). (2010). NHPCO Facts and Figures: Hospice Care in America.
36 Connor SR, Teno J, Spence C, et al. (2005). Family Evaluation of Hospice Care: Results From Voluntary Submission of Data Via Website. Journal of Pain & Symptom Management.
37 Mosenthal AC, Weissman DE, Curtis JR, et al. (2011). Integrating palliative care in the surgical and trauma intensive care unit: A report from the Improving Palliative Care in the Intensive Care Unit (IPAL-ICU) Project Advisory Board and the Center to Advance Palliative Care. Crit Care Med.
38 Herman AD, Johnson TM, Ritchie CS, et al. (2009). Pain management interventions in the nursing home: a structured review of the literature. J Am Geriatr Soc.
39 National Quality Forum. (2006). A national framework and preferred practices for palliative and hospice care quality.
40 Seow H, Snyder CF, Mularski RA, et al. (2009). A framework for assessing quality indicators for cancer care at the end of life. J Pain Symptom Manage.
41 National Consensus Project for Quality Palliative Care (NCP). (2009). Clinical Practice Guidelines for Quality Palliative Care, Second Edition.
42 Durham DD, Rokoske FS, Hanson LC, et al. (2011). Quality improvement in hospice: adding a big job to an already big job?. Am J Med Qual.
43 Shojania KG, McDonald KM, Wachter RM, et al. (2004). Closing The Quality Gap: A Critical Analysis of Quality Improvement Strategies, Volume 1Series Overview and Methodology.
44 Quinn C, Bailey ME. (2011). Caring for children and families in the community: experiences of Irish palliative care clinical nurse specialists. Int J Palliat Nurs.
45 Danz MS, Rubenstein LV, Hempel S, et al. (2010). Identifying quality improvement intervention evaluations: is consensus achievable?. Qual Saf Health Care.
46 Boonyasai RT, Windish DM, Chakraborti C, et al. (2007). Effectiveness of teaching quality improvement to clinicians: a systematic review. JAMA.
47 Nelson JE, Bassett R, Boss RD, et al. (2010). Models for structuring a clinical initiative to enhance palliative care in the intensive care unit: a report from the IPAL-ICU Project (Improving Palliative Care in the ICU). Crit Care Med.
48 Cook AM, Finlay IG, Edwards AG, et al. (2001). Efficiency of searching the grey literature in palliative care. J Pain Symptom Manage.
49 (2004). Gysels M, Higginson IJ, editors. Improving Supportive and Palliative Care for Adults With Cancer. Research Evidence Manual.
50 The Cochrane Collaboration. (2009). Higgins JPT, G S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2.
51 (2011). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
52 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency For Healthcare Research And Quality and the Effective Health Care Program. J Clin Epidemiol.
53 Bookbinder M, Blank AE, Arney E, et al. (2005). Improving end-of-life care: development and pilot-test of a clinical pathway. J Pain Symptom Manage.
54 Casarett D, Karlawish J, Morales K, et al. (2005). Improving the use of hospice services in nursing homes: a randomized controlled trial. JAMA.
55 Cohen LM, Ruthazer R, Germain MJ. (2010). Increasing hospice services for elderly patients maintained with hemodialysis. J Palliat Med.
56 Aiken LS, Butner J, Lockhart CA, et al. (2006). Outcome evaluation of a randomized trial of the PhoenixCare intervention: program of case management and coordinated care for the seriously chronically ill. J Palliat Med.
57 Bakitas M, Lyons KD, Hegel MT, et al. (2009). Effects of a palliative care intervention on clinical outcomes in patients with advanced cancer: the Project ENABLE II randomized controlled trial. JAMA.
58 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. (2000). Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA: the Journal of the American Medical Association.
59 Jordhoy MS, Fayers P, Loge JH, et al. (2001). Quality of life in palliative cancer care: results from a cluster randomized trial. J Clin Oncol.
60 McMillan SC, Small BJ, Haley WE. (2011). Improving hospice outcomes through systematic assessment: a clinical trial. Cancer Nurs.
61 Mitchell GK, Del Mar CB, O'Rourke PK, et al. (2008). Do case conferences between general practitioners and specialist palliative care services improve quality of life? A randomised controlled trial (ISRCTN 52269003). Palliative Medicine.
62 Moore S, Corner J, Haviland J, et al. (2002). Nurse led follow up and conventional medical follow up in management of patients with lung cancer: randomised trial. BMJ.
63 Rabow MW, Dibble SL, Pantilat SZ, et al. (2004). The comprehensive care team: a controlled trial of outpatient palliative medicine consultation. Arch Intern Med.
64 Temel JS, Greer JA, Muzikansky A, et al. (2010). Early palliative care for patients with metastatic non-small-cell lung cancer. The New England Journal of Medicine.
65 Brumley RD, Enguidanos S, Cherin DA. (2003). Effectiveness of a home-based palliative care program for end-of-life. J Palliat Med.
66 Brumley R, Enguidanos S, Jamison P, et al. (2007). Increased satisfaction with care and lower costs: results of a randomized trial of in-home palliative care. J Am Geriatr Soc.
67 Engelhardt JB, McClive-Reed KP, Toseland RW, et al. (2006). Effects of a program for coordinated care of advanced illness on patients, surrogates, and healthcare costs: a randomized trial. Am J Manag Care.
68 Woo J, Cheng JO, Lee J, et al. (2011). Evaluation of a continuous quality improvement initiative for end-of-life care for older noncancer patients. J Am Med Dir Assoc.
69 Dudgeon DJ, Knott C, Eichholz M, et al. (2008). Palliative Care Integration Project (PCIP) quality improvement strategy evaluation. J Pain Symptom Manage.
70 Fang HF, Jhing HY, Lin CC. (2009). Hu Li Za Zhi.
71 Reymond L, Israel FJ, Charles MA. (2011). A residential aged care end-of-life care pathway (RAC EoLCP) for Australian aged care facilities. Aust Health Rev.
72 Ringdal GI, Jordhoy MS, Kaasa S. (2002). Family Satisfaction With End-of-Life Care for Cancer Patients in a Cluster Randomized Trial. Journal of Pain & Symptom Management.
73 Pantilat SZ, O'Riordan DL, Dibble SL, et al. (2010). Hospital-based palliative medicine consultation: a randomized controlled trial. Arch Intern Med.
74 Badger F, Clifford C, Hewison A, et al. (2009). An evaluation of the implementation of a programme to improve end-of-life care in nursing homes. Palliat Med.
75 Luhrs CA, Meghani S, Homel P, et al. (2005). Pilot of a pathway to improve the care of imminently dying oncology inpatients in a Veterans Affairs Medical Center. J Pain Symptom Manage.
76 Kitchener HC, Fletcher I, Roberts C, et al. (2008). The psychosocial impact of human papillomavirus testing in primary cervical screening - a study within a randomized trial. International Journal of Gynecological Cancer.
77 Bailey FA, Burgio KL, Woodby LL, et al. (2005). Improving processes of hospital care during the last hours of life. Arch Intern Med.
78 Jordhoy MS, Fayers P, Saltnes T, et al. (2000). A Palliative-Care Intervention and Death at Home: a Cluster Randomised Trial. Lancet.
79 Ringdal GI, Jordhoy MS, Ringdal K, et al. (2001). The First Year of Grief and Bereavement in Close Family Members to Individuals Who Have Died of Cancer. Palliative Medicine.
80 van der Heide A, Veerbeek L, Swart S, et al. (2010). End-of-life decision making for cancer patients in different clinical settings and the impact of the LCP. J Pain Symptom Manage.
81 Ward S, Donovan HS, Owen B, et al. (2000). An individualized intervention to overcome patient-related barriers to pain management in women with gynecologic cancers. Research in Nursing & Health.
82 Wilkie D, Berry D, Cain K, et al. (2010). Effects of coaching patients with lung cancer to report cancer pain. Western Journal of Nursing Research.
83 Borneman T, Koczywas M, Cristea M, et al. (2008). An interdisciplinary care approach for integration of palliative care in lung cancer. Clin Lung Cancer.
84 Fuchs LS, Hadjistavropoulos T, Lix L. (2008). Pain Assessmentas Intervention: a Study of Older Adults with Severe Dementia. Clinical Journal of Pain.
85 Kovach CR, Logan BR, Noonan PE, et al. (2006). Effects of the Serial Trial Intervention on discomfort and behavior of nursing home residents with dementia. American Journal of Alzheimer's Disease and Other Dementias.
86 Aubin M, Vezina L, Parent R, et al. (2006). Impact of an educational program on pain management in patients with cancer living at home. Oncol Nurs Forum.
87 van der Peet EH, van den Beuken-van Everdingen MH, et al. (2008). Randomized clinical trial of an intensive nursing-based pain education program for cancer outpatients suffering from pain. Support Care Cancer.
88 Lovell MR, Forder PM, Stockler MR, et al. (2010). A randomized controlled trial of a standardized educational intervention for patients with cancer pain. J Pain Symptom Manage.
89 Marinangeli F, Ciccozzi A, Leonardis M, et al. (2004). Use of strong opioids in advanced cancer pain: a randomized trial. J Pain Symptom Manage.
90 Oldenmenger WH, Sillevis Smitt PA, van Montfort CA, et al. (2011). A combined pain consultation and pain education program decreases average and current pain and decreases interference in daily life by pain in oncology outpatients: a randomized controlled trial. Pain.
91 Du Pen AR, Du Pen S, Hansberry J, et al. (2000). An educational implementation of a cancer pain algorithm for ambulatory care. Pain Manag Nurs.
92 Borneman T, Koczywas M, Sun VC, et al. (2010). Reducing patient barriers to pain and fatigue management. J Pain Symptom Manage.
93 Miaskowski C, Dodd M, West C, et al. (2004). Randomized clinical trial of the effectiveness of a self-care intervention to improve cancer pain management. J Clin Oncol.
94 Miaskowski C, Dodd M, West C, et al. (2007). The use of a responder analysis to identify differences in patient outcomes following a self-care intervention to improve cancer pain management. Pain.
95 Given B, Given CW, McCorkle R, et al. (2002). Pain and fatigue management: results of a nursing randomized clinical trial. Oncol Nurs Forum.
96 Syrjala KL, Abrams JR, Polissar NL, et al. (2008). Patient training in cancer pain management using integrated print and video materials: a multisite randomized controlled trial. Pain.
97 Anderson KO, Mendoza TR, Payne R, et al. (2004). Pain education for underserved minority cancer patients: a randomized controlled trial. J Clin Oncol.
98 Wells N, Hepworth JT, Murphy BA, et al. (2003). Improving cancer pain management through patient and family education. J Pain Symptom Manage.
99 Oliver JW, Kravitz RL, Kaplan SH, et al. (2001). Individualized patient education and coaching to improve pain control among cancer outpatients. Journal of Clinical Oncology: Official Journal of the American Society of Clinical Oncology.
100 Ward S, Donovan H, Gunnarsdottir S, et al. (2008). A randomized trial of a representational intervention to decrease cancer pain (RIDcancerPain). Health Psychol.
101 Jane SW, Wilkie DJ, Gallucci BB, et al. (2009). Effects of a full-body massage on pain intensity, anxiety, and physiological relaxation in Taiwanese patients with metastatic bone pain: a pilot study. J Pain Symptom Manage.
102 Keefe FJ, Ahles TA, Sutton L, et al. (2005). Partner-guided cancer pain management at the end of life: a preliminary study. J Pain Symptom Manage.
103 Lema MJ. (2002). Emerging options with coxib therapy. Cleve Clin J Med.
104 Dalton JA, Keefe FJ, Carlson J, et al. (2004). Tailoring cognitive-behavioral treatment for cancer pain. Pain Manag Nurs.
105 Dighe M, Jadhav S, Muckaden MA, et al. (2008). Parental Concerns in Children Requiring Palliative Care. Indian Journal of Palliative Care.
106 Teno JM, Mor Vincent, Weitzen Sherry, et al. (2001). ‘persistent Pain in Nursing Home Residents’: Reply. Jama: Journal of the American Medical Association.
107 Kalauokalani D, Franks P, Oliver JW, et al. (2007). Can patient coaching reduce racial/ethnic disparities in cancer pain control? Secondary analysis of a randomized controlled trial. Pain Med.
108 Carlson LE, Groff SL, Maciejewski O, et al. (2010). Screening for distress in lung and breast cancer outpatients: a randomized controlled trial. J Clin Oncol.
109 Blumenthal JA, Babyak MA, Keefe FJ, et al. (2006). Telephone-based coping skills training for patients awaiting lung transplantation. Journal of Consulting and Clinical Psychology.
110 Walsh K, Jones L, Tookman A, et al. (2007). Reducing emotional distress in people caring for patients receiving specialist palliative care. Randomised trial. Br J Psychiatry.
111 Aranda S, Schofield P, Weih L, et al. (2006). Meeting the support and information needs of women with advanced breast cancer: a randomised controlled trial. Br J Cancer.
112 Porter LS, Keefe FJ, Garst J, et al. (2010). Caregiver-Assisted Coping Skills Training for Lung Cancer: Results of a Randomized Clinical Trial. J Pain Symptom Manage.
113 Steel JL, Nadeau K, Olek M, et al. (2007). Preliminary results of an individually tailored psychosocial intervention for patients with advanced hepatobiliary carcinoma. J Psychosoc Oncol.
114 Hudson PL, Aranda S, Hayman-White K. (2005). A psycho-educational intervention for family caregivers of patients receiving palliative care: a randomized controlled trial. J Pain Symptom Manage.
115 Ritchie L. (2011). Planning end-of-life care. Nurs N Z.
116 Meeussen K, L, Echteld M, et al. (2011). End-of-Life Care and Circumstances of Death in Patients Dying As a Result of Cancer in Belgium and the Netherlands: A Retrospective Comparative Study. Journal of Clinical Oncology.
117 Gade G, Venohr I, Conner D, et al. (2008). Impact of an inpatient palliative care team: a randomized control trial. J Palliat Med.
118 Hanks GW, Robbins M, Sharp D, et al. (2002). The imPaCT study: a randomised controlled trial to evaluate a hospital palliative care team. British Journal of Cancer.
119 Campbell ML, Guzman JA. (2003). Impact of a proactive approach to improve end-of-life care in a medical ICU. Chest.
120 Schneiderman LJ, Gilmer T, Teetzel HD, et al. (2003). Effect of ethics consultations on nonbeneficial life-sustaining treatments in the intensive care setting: a randomized controlled trial. JAMA.
121 Schneiderman LJ, Gilmer T, Teetzel HD. (2000). Impact of ethics consultations in the intensive care setting: a randomized, controlled trial. Crit Care Med.
122 Clayton JM, Butow PN, Tattersall MH, et al. (2007). Randomized controlled trial of a prompt list to help advanced cancer patients and their caregivers to ask questions about prognosis and end-of-life care. J Clin Oncol.
123 Tulsky J, Arnold R, Alexander S, et al. (2011). Enhancing communication between oncologists and patients with a computer-based training program: a randomized trial. Annals of Internal Medicine.
124 Lilly CM, Sonna LA, Haley KJ, et al. (2003). Intensive communication: four-year follow-up from a clinical practice study. Crit Care Med.
125 Jacobsen Juliet, Robinson Ellen, Jackson VA, et al. (2011). Development of a Cognitive Model for Advance Care Planning Discussions: Results From a Quality Improvement Initiative. Journal of Palliative Medicine.
126 Lilly CM, De Meo DL, Sonna LA, et al. (2000). An intensive communication intervention for the critically ill. Am J Med.
127 Ahrens T, Yancey V, Kollef M. (2003). Improving family communications at the end of life: implications for length of stay in the intensive care unit and resource use. Am J Crit Care.
128 Mosenthal AC, Murphy PA, Barker LK, et al. (2008). Changing the culture around end-of-life care in the trauma intensive care unit. J Trauma.
129 Kaufer M, Murphy P, Barker K, et al. (2008). Family satisfaction following the death of a loved one in an inner city MICU. Am J Hosp Palliat Care.
130 Norton SA, Hogan LA, Holloway RG, et al. (2007). Proactive palliative care in the medical intensive care unit: effects on length of stay for selected high-risk patients. Crit Care Med.
131 Molloy DW, Guyatt GH, Russo R, et al. (2000). Systematic implementation of an advance directive program in nursing homes: a randomized controlled trial. JAMA.
132 Lautrette A, Darmon M, Megarbane B, et al. (2007). A communication strategy and brochure for relatives of patients dying in the ICU. N Engl J Med.
133 Sampson EL, Jones L, Thune-Boyle IC, et al. (2011). Palliative assessment and advance care planning in severe dementia: an exploratory randomized controlled trial of a complex intervention. Palliat Med.
134 Penticuff JH, Arheart KL. (2005). Effectiveness of an intervention to improve parent-professional collaboration in neonatal intensive care. J Perinat Neonatal Nurs.
135 Campion FX, Larson LR, Kadlubek PJ, et al. (2011). Advancing performance measurement in oncology. Am J Manag Care.
136 McMillan SC, Small BJ. (2007). Using the COPE intervention for family caregivers to improve symptoms of hospice homecare patients: a clinical trial. Oncol Nurs Forum.
137 McMillan SC, Small BJ, Weitzner M, et al. (2006). Impact of coping skills intervention with family caregivers of hospice patients with cancer: a randomized clinical trial. Cancer.
138 Keay TJ, Alexander C, McNally K, et al. (2003). Nursing home physician educational intervention improves end-of-life outcomes. J Palliat Med.
139 Hanson LC, Reynolds KS, Henderson M, et al. (2005). A quality improvement intervention to increase palliative care in nursing homes. J Palliat Med.
140 Velikova G, Booth L, Smith AB, et al. (2004). Measuring quality of life in routine oncology practice improves communication and patient well-being: a randomized controlled trial. J Clin Oncol.
141 Velikova G, Keding A, Harley C, et al. (2010). Patients report improvements in continuity of care when quality of life assessments are used routinely in oncology practice: secondary outcomes of a randomised controlled trial. Eur J Cancer.
142 Mills ME, Murray LJ, Johnston BT, Cardwell C, Donnelly M. (2009). Does a patient-held quality-of-life diary benefit patients with inoperable lung cancer?. J Clin Oncol.
143 Detmar SB, Muller MJ, Schornagel JH, et al. (2002). Health-related quality-of-life assessments and patient-physician communication: a randomized controlled trial. JAMA.
144 Rosenbloom SK, Victorson DE, Hahn EA, et al. (2007). Assessment Is Not Enough: a Randomized Controlled Trial of the Effects of Hqrl Assessment on Quality of Life and Satisfaction in Oncology Clinical Practice. Psycho-Oncology.
145 Taenzer P, Bultz BD, Carlson LE, et al. (2000). Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology.
146 Jacobs LG, Bonuck K, Burton W. (2002). Can “Palliative Care Reports” improve end-of-life care for hospitalized patients?. J Pain Symptom Manage.
147 Sherwood P, Given BA, Given CW, et al. (2005). A cognitive behavioral intervention for symptom management in patients with advanced cancer. Oncology Nursing Forum.
148 Sikorskii A, Given CW, Given B, et al. (2007). Symptom Management for Cancer Patients: a Trial Comparing Two Multimodal Interventions. Journal of Pain & Symptom Management.
149 Miller JJ, Frost MH, Rummans TA, et al. (2007). Role of a medical social worker in improving quality of life for patients with advanced cancer with a structured multidisciplinary intervention. J Psychosoc Oncol.
150 Neubauer A, Wolf M, Engenhart-Cabillic R, et al. (2002). Dtsch Med Wochenschr.
151 Meyers FJ, Carducci M, Loscalzo MJ, et al. Effects of a problem-solving intervention (COPE) on quality of life for patients with advanced cancer on clinical trials and their caregivers: simultaneous care educational intervention (SCEI): linking palliation and clinical trials.
152 Holt TR, Yau VK. (2010). Innovative program for palliative radiotherapy in Australia. J Med Imaging Radiat Oncol.
153 Curtis JR, Treece PD, Nielsen EL, et al. (2008). Integrating palliative and critical care: evaluation of a quality-improvement intervention. Am J Respir Crit Care Med.
154 Curtis JR, Nielsen EL, Treece PD, et al. (2011). Effect of a quality-improvement intervention on end-of-life care in the intensive care unit: a randomized trial. Am J Respir Crit Care Med.
155 Goodwin DM, Higginson IJ, Myers K, et al. (2003). Effectiveness of palliative day care in improving pain, symptom control, and quality of life. J Pain Symptom Manage.
156 Grande GE, Todd CJ, Barclay SI, et al. (2000). A randomized controlled trial of a hospital at home service for the terminally ill. Palliat Med.
157 Kroenke K, Theobald D, Wu J, et al. (2010). Effect of telecare management on pain and depression in patients with cancer: a randomized trial. JAMA.
158 Stiefelhagen P. (2011). MMW Fortschr Med.