# Introduction

## Background and Context

Extensive evidence supports the effectiveness of clinical interventions for improving patient-centered outcomes for patients with advanced and serious illness. For example, many types of medications and other interventions to treat pain,1 can lead to significant reductions in pain severity and pain-related outcomes such as quality of life.2 However, studies in different areas have found that these are often not well integrated into medical practice. For pain, despite widely accepted pain screening and clinical practice guidelines,3 pain continues to be undertreated, particularly for vulnerable populations such as nursing home patients.4 For communication and decisionmaking, in a study of audiotaped initial oncology consultations for patients with terminal cancer, fewer than half of oncologists offered alternatives to chemotherapy as an option. In addition, only 58 percent of patients were informed of their life expectancy and only 60 percent were aware of uncertainty about the benefits of chemotherapy.5 And despite wide availability and insurance coverage of hospice care, in 2009, only 42 percent of patients who died in the United States received any hospice care, and, of those, only half received more than three weeks of care.6

This report is part of a larger review of interventions aimed at reducing the quality gap (the difference between health care processes or outcomes observed in practice and evidence-based practices potentially obtainable on the basis of current professional knowledge).7 Given the critical importance of interventions to improve health care and palliative care in this population, we focused on these types of interventions in this report. These interventions can include changes in the way care is provided within a system, such as palliative care consultation services, and interventions to change how patients/families interact with the health care system, such as a patient self-management program for pain that is integrated with patients' health care. They can also include quality improvement interventions, (quality improvement; see Appendix A for a list of acronyms) which can be defined as any type of intervention to improve care with some element of system change, including change in how patients/families interact with the health care system, and can be delivered through a variety of quality improvement methods, such as continuous quality improvement. The common purpose of these types of interventions is to improve care and self-management to maximize the quality of life of people facing advanced and serious illnesses and the end of life and of their families. This includes relief from physical and psychosocial symptoms; psychosocial and spiritual support for both the patient and their families and other caregivers; excellent communication about topics such as prognosis; person-centered care, with compassion, personalization, and cultural sensitivity; care planning and prevention of crises; and opportunities for comfortable dying, life closure, and control of the circumstances of death.

For the purposes of this review, we address the needs of patients with advanced and serious illnesses through the three interrelated areas of palliative care, end-of-life care, and hospice care. Palliative care is defined as medical care focused on improving the quality of life of people facing serious or life-threatening illness, including the end of life. It is often provided as a service or quality improvement intervention, and can be delivered in any setting. Emphasis is placed on pain and symptom management, communication, and coordinated care. End-of-life care is defined as care delivered to dying patients, and is a small subset of palliative care. Hospice is also a subset of palliative care and is defined as a care delivery system and insurance benefit for patients in the last months of life who have chosen quality of life as the primary goal of care, and which is provided, in the United States, wherever the patient resides. In the United States, these include the home, special inpatient units, and nursing homes.

We focused on several specific targets that are critical to improving care in this population: continuity, coordination of care, and transitions; pain; distress; and communication and decisionmaking. The next sections define these targets and health care and palliative care interventions that might improve them, and summarize evidence from previous systematic reviews for the targets and settings that are the focus of this review.

### Continuity, Coordination of Care, and Transitions

Continuity can be defined as the exchange of knowledge and the relationships between providers and patients/families, or between providers and/or provider groups. Continuity includes three areas: relational continuity, focusing on the relationship between patients/families and providers; management continuity, focusing on the relationship between providers (e.g., developing interdisciplinary teams); and informational continuity, focused on improving information exchange (e.g., improving patient assessment in palliative care domains). Coordination of care is a challenge for many patients with serious illness, including aligning care across settings; communicating with physicians; and incorporating multiple complex treatments for the patient. Improving transitions includes both improving the process of transitions that occur, and facilitating the initiation of appropriate transitions, such as enrollment in hospice care. Specialized palliative care services usually involve an interdisciplinary team, usually a physician and a nurse, social worker, pharmacist, and/or chaplain. Services focus on continuity and coordination of care, including assisting with transitions to hospice, and also include communication, decisionmaking support, and care planning, symptom management, and psychosocial, spiritual, and bereavement support. Because of these services' focus on continuity and coordination, and for consistency with an earlier systematic review,8 we classified these services in the target of continuity.

Several previous systematic reviews have addressed the target of continuity in palliative care, although one review addressed populations with serious illness much more broadly, and the other two focused solely on specialized palliative care interventions, and none of the reviews addressed broader quality improvement interventions in this target or the role of quality improvement within palliative care interventions. A review through 2006 on evidence for improving palliative care, addressing broader populations with chronic illness,8 defined continuity as addressing relationships with providers over time. The review found that studies in congestive heart failure, dementia, and nursing homes (many focusing on case management and transitions), generally did not focus on end-of-life populations or issues. The review also found two previous systematic reviews on this topic in end-of-life care. One review of case management in end-of-life care identified four RCTs, with two that evaluated utilization, having mixed effects. A review of improved coordination for supportive cancer care identified nine RCTs of portable records (mostly negative studies) or palliative care–home care coordination (with mixed effects for patient and caregiver outcomes and utilization). The review identified one additional study specific to end-of-life care, which found that palliative case managers increased advance directives and lowered utilization.

Several systematic reviews have addressed the effectiveness of specialized palliative care both generally,8-12 and in AIDS13 and cancer14,15 populations. The most recent review addressing all populations11 focused on RCTs of specialized palliative care (trained professionals) published through 2007. Outcomes included quality of life, satisfaction, or costs; half were in the home setting, and half focused on cancer patients; 12 of the studies evaluated a multidisciplinary team. The review found the strongest evidence for effectiveness in the area of satisfaction (seven out of the 10 studies evaluated that outcome found a significant impact of the intervention), compared to four out of the 13 studies that evaluated quality of life outcomes (although almost all of these studies were underpowered) and only one out of seven studies evaluating the outcome of cost.

The most recent review on specialized palliative care in cancer14 focused on similar outcomes, and concluded that there was evidence for effectiveness for palliative care in both the home and hospital setting, mainly for the outcomes of pain and symptom management, hospital admissions, and satisfaction. Some improvements were also noted in anxiety and depression and caregiver quality of life. This review also found less evidence for effectiveness in patient quality of life.

### Pain

Pain is one of the most common symptoms in individuals with cancer that is directly associated with significantly reduced quality of life.16,17 Poorly-managed cancer pain is an important quality of care outcome and a high priority for patients, clinicians, and health care policy. A recent systematic review estimated that among individuals with metastatic cancer, an average of 64 percent of patients experienced pain.18 Cancer pain is most commonly the result of tumor load,19 but is also frequently associated with treatments, such as surgery or chemotherapy. Because pain is implicated with disease progression, frequent reassessment and changes in management are required to ensure quality of life and care.20 Yet, despite the importance of pain ascertainment and management, under-treatment is common,21 affecting as many as 40 percent of patients.22

Quality improvement strategies to improve pain management in patients with advanced and serious illness include patient and caregiver education, provider education, systematic pain assessment, and use of clinical decision tools to improve appropriate prescribing of analgesia. Several prior systematic reviews addressing the impact of quality improvement interventions for pain in patients in various stages of cancer, have demonstrated mixed findings. A 2001 review of pain management interventions found evidence that quality improvement interventions focused on providers improved provider knowledge and attitudes, but did not have significant positive impact on patient pain ratings.23 While provider-focused interventions were not found to be effective in this review, nurse-led patient directed educational interventions were found to have a positive effect on patient pain levels. Moreover, systematic pain assessment was found to have some promise in improving patient pain outcomes. A 2009 systematic review and meta-analysis of patient-based educational interventions24 included 21 trials (19 RCTs), 15 of which were included in a meta-analysis which found that interventions successfully reduced both average and worst pain intensity.

A systematic review focusing on studies of hospitalized cancer patients25 found five studies addressing education, audit and feedback, decision support, and pain consultation. Some evidence was found for the impact of interventions on satisfaction and quality of care, but not for pain outcomes. A 2007 review26 found effective studies in the domains of institutionalization models (e.g., routine pain assessment), clinical pathways, and pain consultation. A 2011 review of knowledge translation interventions targeted at improving cancer pain through either health care providers or patients and family caregivers found that, generally, knowledge translation had a positive impact on pain outcomes. Better outcomes were observed with higher frequency and intensity of educational programs.27 These reviews all addressed pain in broad populations with cancer or hospitalized patients, and did not focus on patients with advanced disease or serious illness, who have different types of pain management needs and may require different quality improvement approaches.

### Distress

Distress can be defined as a multifactorial unpleasant emotional experience of a psychological (cognitive, behavioral, emotional), social, and/or spiritual nature that may interfere with the ability to cope effectively with illness, its physical symptoms and its treatment.28 The term is broader than specific psychiatric diagnoses such as depression, and can apply to the psychosocial and emotional impact of illness on both patients and caregivers/families. Recommended interventions to include distress include screening in the cancer care setting, psychosocial interventions such as social work consultation and counseling, and spiritual counseling.

Several systematic reviews have addressed psychosocial interventions for family caregivers in palliative care29 and in adult30 and adolescent31 cancer patients, as well as psychotherapy for depression in incurable cancer patients.32 Although these reviews did find some evidence for the effectiveness of these types of interventions, they generally did not focus on distress as an outcome or end-stage illnesses, and did not address the issue of quality improvement for this target.

### Communication and Decisionmaking

Effective communication and decisionmaking between providers, and between providers and patients and families, constitutes the foundation for the tasks of palliative care. Thus, the quality of communication for patients with advanced and serious illness is a key determinant of patient and family outcomes. Key aspects of communication and decisionmaking with this population include: sharing information about diagnosis, prognosis and goals of care; engaging families in treatment decisionmaking; and offering psychosocial support. Interventions include increasing the frequency of communication about these issues (such as regularly scheduled family meetings), and increasing the quality of communication (such as implementing structured templates).

Several previous systematic reviews have focused on quality improvement in communication in relevant areas. Lorenz et al,9 in a 2008 systematic review, found moderate evidence supporting effectiveness of interventions to increase advance directive rates, although little evidence on patient outcomes. The review also identified studies supporting the effectiveness of a variety of communication interventions. In a 2008 review, Walling et al.33 found similar results, and also found that broader end-of-life communication interventions had demonstrated effectiveness for patient satisfaction and psychological outcomes. Finally, a 2011 review of studies focusing on communication in the intensive care setting34 found evidence supporting the effectiveness of regular, structured communication and palliative care and ethics consultations for the outcomes of distress and health care utilization.

### Settings of Care

End-of-life care occurs across all settings, and interventions identified in previous systematic reviews have focused mainly on the hospital and home setting, with some interventions in the outpatient, hospice, and nursing home setting. Quality improvement is important in hospices, which are specifically focused on end-of-life care, because variation in quality also exists within hospice programs. In the Family Evaluation of Hospice Care from the National Hospice and Palliative Care Organization,35 (completed, in a general hospice population including patients with cancer and other illnesses, by families after hospice patients' deaths), 18.2 percent of family members noted problems with attention to family needs for support (variation among hospices, 25th and 75th percentiles, 12.6 and 21.4 percent), and 9.8 percent of family members reported unmet need for emotional support (variation among hospices, 25th and 75th percentiles, 5.4 and 13.3 percent).36 No previous systematic reviews focused on quality improvement in the hospice setting. Because of this, and because of the importance of hospice care in end-of-life care and current quality improvement initiatives, we focused specifically on this setting as part of our review.

Approximately 20 percent of deaths in the United States occur in nursing homes or shortly after transfer from a nursing home to a hospital.37 Evidence on palliative care in nursing homes has demonstrated major deficits in palliative care processes such as advance care planning, pain management, and psychosocial support. Two systematic reviews have focused on quality improvement in nursing homes, but did not focus on end-of-life populations. One of these reviews, targeting pain management,38 identified a variety of quality improvement studies using provider education, decision support, and systems changes, but found few high-quality studies and high reliance on process rather than patient outcomes. Because of the lack of previous reviews focusing on end-of-life care in the nursing home setting, and because of the importance of this setting to end-of-life care, we also focused on this setting in our review.

## Scope

Current approaches to providing palliative care or improving quality in key patient-centered targets in advanced and serious illness (e.g., the targets of communication and pain) vary widely, and there is clear need for information on what types of interventions can improve palliative care for patients. Although there have been a number of systematic reviews related to this topic, recent reviews have focused mainly on palliative care and hospice interventions and on specific domains, settings, or populations (e.g., communication, intensive care unit, cancer), and none have used the perspective of quality improvement. There are some studies of different types of interventions (case management, ordersets, and improvement of communication), but they are not specifically addressed in these reviews, and key reviews of pain interventions in cancer and nursing homes have not focused on patients with advanced illness.

With regard to hospice, in spite of the huge range of quality improvement interventions (case management, provider and patient education, targeted patient interventions, structured ordersets, and patient screening for eligibility for palliative care services or specific needs), little systematic information is available on which types of interventions work for hospice. This lack of evidence is especially notable since providers are now required by the Center for Medicare and Medicaid Services to have a quality assurance program with a quality improvement component.

## Framework for the Systematic Review

The framework (Figure 1) is derived from the National Quality Forum palliative care framework and a recent consensus project conducted to develop a framework for end-of-life cancer quality measurement.39,40 The framework shows the literature in end-of-life care as a grid, with different populations, domains of care, targets of quality improvement, settings (and integrated care), and categories of quality improvement relevant to palliative care.

Figure 1 Analytic framework for interventions for advanced and serious illness systematic review

Figure 1. Framework for end-of-life and hospice care systematic review. This framework defines the populations under study for end-of-life (EOL) quality improvement, the domains of EOL quality improvement, the targets for EOL quality improvement, settings, and quality improvement interventions under consideration.

The targets show the areas where an intervention might focus—such as an intervention specifically targeting pain management in patients with advanced disease To apply the framework for prioritizing areas for the review, we conducted an initial environmental scan of systematic reviews, consulted with experts, and considered needs of key stakeholders and audiences for the review, to determine domains and settings where this review would be most valuable. Underlined areas show where we prioritized the searches and review, but all areas in the framework were included. For the first Key Question, we included targets where there was a substantial literature but not covered in recent reviews, and two settings of particular interest to key audiences and not covered in recent reviews. In the second Key Question, we focus on types and models of quality improvement, applying them to studies both in specific target areas and to studies addressing multiple targets. We designed the scope in this way to focus on key areas in end-of-life care that had not been addressed in previous reviews and to make the results of our review focused enough to draw clear conclusions.

## Key Questions

### Key Question 1 What is the effectiveness of health care and palliative care interventions for improving the quality of palliative care?

a. Specific targets: What is the effectiveness in terms of processes and outcomes for pain; communication and decisionmaking; continuity, coordination, and transitions; and patient and family distress; in palliative care populations? (See Figure 1, Framework for end-of-life and hospice care, column 3, for a listing of targets of quality improvement.)
b. Specific settings: What is the effectiveness for interventions for any target of palliative care within hospice programs or nursing homes?

### Key Question 2 What is the evidence for different quality improvement models for improving palliative care?

a. What is the evidence for different types of quality improvement interventions? (See the Interventions section below and framework, column 5 of Figure 1.)
b. What is the evidence for different models in palliative care: integrative, compared with consultative? (See column 5 of Figure 1, framework, for definitions.)

We evaluated each target for whether Key Question 2a or 2b was most applicable, and only one of these questions was analyzed for each target (they were mutually exclusive).

The intent of the Key Questions was to describe the evidence in each area (e.g., target, quality improvement type, setting), not to compare the different areas to each other.

“Targets” relate to the targets of the intervention, e.g. pain; communication and decisionmaking; continuity, coordination, and transitions; and patient and family distress, and not outcomes (see column 3 in the framework).

“Integrative” refers to interventions that embed palliative care principles and interventions into daily practice, and “consultative” refers to interventions that increase the use and effectiveness of palliative care consultants or other non-integrative interventions (see column 5 in the framework)

## Uses of This Report

Audiences who might find value from the report include professionals in both palliative care and hospice programs, as well as those in other settings with a significant percentage of patients with serious and advanced disease, such as cancer centers, medicine inpatient units, and nursing homes. Other potential audiences include health care professionals (e.g., physicians, nurses, social workers, and pharmacists) and relevant health care professional organizations (e.g., Academy of Hospice and Palliative Medicine, Hospice and Palliative Nurses Association), for quality initiatives and education; key funders in this area (e.g., National Cancer Institute, National Institute on Aging, National Institute of Nursing Research); and staff of organizations investing in palliative care quality improvement and systems initiatives (e.g., Center for Medicare and Medicaid Services, Veterans Health Administration, Kaiser, Institute for Healthcare Improvement), as well as organizations representing hospice and palliative care programs (e.g., the National Hospice and Palliative Care Organization). Researchers in palliative care and relevant fields, as well as relevant policymakers (e.g., The National Quality Forum's National Priorities Partnership39) and members and staff of advocacy groups (e.g., American Cancer Society) will also be able to use the contents of the review. This report may be useful to help researchers plan areas to target and intervention types and outcome measures to use; and for health care organizations' decisionmaking on what types of programs to implement.