# Peer Reviewers

Amy Abernethy

Division of Medical Oncology

Department of Medicine

Duke University School of Medicine

Director, Duke Cancer Care Research Program

Durham, NC

Constance Dahlin

Clinical Director

Palliative Care Services

Massachusetts General Hospital

Boston, MA

Betty Ferrell

Nursing Research and Education

2012 City of Hope

Duarte, CA

Laura Hanson

Division of Geriatric Medicine

Associate Director of the Fellowship Program

School of Medicine

Co-Director, UNC Palliative Care Program

Division of Geriatric Medicine

School of Medicine

University of North Carolina

Chapel Hill, NC

June Lunney

Director of Research

Hospice and Palliative Care Nurses' Association (HPNA)

Arlington, VA

Naomi Naierman

President and CEO

American Hospice Foundation

Washington, DC

Joyce Reitzner

Healthcare Informatics, Practice and Research

American College of Chest Physicians

Northbrook, IL

Susie Sherman

Coordinator, Public Affairs & Advocacy

American Geriatrics Society

New York, NY