# Technical Expert Panel

Margaret Campbell, Ph.D., R.N.

Wayne State University

College of Nursing

Detroit, MI

J. Randall Curtis, M.D., M.P.H.

Harborview Medical Center

Seattle, WA

Cindy Massuda

Centers for Medicare & Medicaid Services

Baltimore, MD

Jeri Miller, Ph.D.

National Institute of Nursing Research

Bethesda, MD

Joan Teno, M.D.

Brown Medical School

Providence, RI

Joanne Wolfe, M.D., M.P.H.

Dana-Farber Cancer Institute

Boston, MA

Joan Zlotnik, Ph.D., ACSW

Social Work Policy Institute

National Association of Social Workers Foundation

Washington, DC