# Discussion

## Summary of Key Findings and Strength of Evidence

In summary, we found a significant number and wide variety of studies of interventions to improve health care and palliative care for patients with advanced and serious illness. Studies were highly heterogenous across most targets for study interventions, quality, and outcomes, with many studies evaluating multiple outcomes. Many studies addressed a variety of different types of quality improvement types, particularly for the target of continuity, coordination and transitions. For this target, strength of evidence was moderate for the outcomes of patient and caregiver satisfaction, where four of six studies (67 percent) for patients and four of six studies (67 percent) for caregivers of found a statistically significant improvement with the intervention, and low for other outcomes: three of nine studies (33 percent) found a statistically significant improvement for the outcome of quality of life and none found improvement for the outcome of overall symptoms. Only five of 16 studies (31 percent) of those that evaluated health care utilization as an outcome found a statistically significant effect in favor of the intervention. Studies that included patient-centered quality improvement types, such as education and self-management, had the strongest evidence of effectiveness on patient- and family-centered outcomes such as satisfaction and quality of life, compared to types such as organizational change. On the other hand, studies focusing on provider-focused interventions (e.g., education, reminders) were more likely to have an impact on the outcome of health care utilization than studies focusing on other quality improvement types, although these studies were mainly non-randomized clinical trials (RCTs).

Strength of evidence was moderate for the target and outcome of pain, where almost all of the 21 studies that we included focused on patient education and self-management: 10 studies (47 percent) found a statistically significant improvement of the intervention on pain outcomes compared to the control group. Patient/caregiver education and self-management encompassed most of the pain and distress studies: strength of evidence was moderate for pain, with approximately half of studies showing a significant improvement with the intervention

Strength of evidence was low for distress, where only two of seven included studies (29 percent) found a statistically significant improvement with the intervention on the outcome of distress or depression – a detailed psychosocial screen in the cancer care setting with triage to appropriate services, and a support program for lung transplant candidates; no patient education/self-management programs in cancer patients found an impact.

For communication and decisionmaking, strength of evidence was moderate only for the outcome of health care utilization, where 11 of 15 studies (73 percent) that reported this outcome found a statistically significant impact in favor of the intervention, compared to only 22 percent of studies addressing patient or family satisfaction. Comparing the integrative and consultative models for quality improvement in this target, three-quarters of studies evaluating consultative interventions found a statistically significant improvement with the intervention on at least one key outcome, compared to half of the integrative interventions; no studies directly compared the two models.

In studies addressing other or multiple targets, patient/caregiver education/self-management and facilitated relay of clinical data to providers were the most common quality improvement types. Of four studies focusing on a broad variety of symptoms using patient education/self-management, three had statistically significant findings in favor of the intervention for symptom outcomes. Of studies addressing multiple targets and focusing on the quality improvement type of facilitated relay of clinical data to providers, only one of five demonstrated a statistically significant improvement on either quality of life or satisfaction outcomes.

We found only two studies in hospices that met our inclusion criteria, both of which found a statistically significant improvement on at least one key outcome, and nine in nursing homes, seven of which demonstrated a significant improvement of the intervention on at least one outcome (with too few studies and diverse outcomes to make substantive conclusions about strength of evidence).

In this literature, we found that studies addressed a wide variety of illnesses, with many in mixed-cancer or mixed-illness populations. A number of studies also addressed specific cancer types, advanced pulmonary disease, and congestive heart failure, and one study focused on communication in extremely-low birthweight infants. We found a wide distribution of studies focusing on combinations of many different types of quality improvement interventions, as well as a variety of studies focusing on just one type of quality improvement intervention. Certain interventions, (e.g., self-management) received more attention than others (e.g., financial and regulatory). We also found a number of studies with multi-faceted interventions that used many quality improvement categories simultaneously.

The taxonomy of quality improvement types generally fit well, although application of the taxonomy to the field of palliative care did require some adjustments in definitions and types of interventions that were included in each category. For example, we found several studies addressing ordersets (usually for comfort care at the end of life), which we categorized as part of provider reminder interventions. We did add one additional category to the quality improvement type taxonomy, provider training in quality improvement methods, although few studies included this element. Across the different targets, the types of quality improvement differed as well, partly because of our inclusion criteria but also because of issues specific to the targets. Both pain and distress studies tended to be focused on patients or caregivers; few system-level distress studies exist, and system-level pain studies are also relatively rare and were not generally limited to patients with advanced disease.25 Continuity interventions included a wide variety of quality improvement types.

In addition, the added dimension of different quality improvement models, separate from the taxonomy of quality improvement types, was important for analyzing quality improvement in this field. Consultation (addition of new services) was important for this area (palliative care consultation is an important element of quality improvement). We used the added dimension of integrative compared to consultative care to capture whether patients' usual providers or added providers were giving care. For the target of communication and decisionmaking, the dichotomy of integrative compared to consultative interventions fit better for study classification than the types of quality improvement.

In terms of the Institute of Medicine domains of quality intervention--efficacy, equity, safety, timeliness, patient-centeredness, and efficiency--studies generally focused on efficacy, patient-centeredness, and effectiveness. For efficacy, symptom outcomes were common, including pain and distress, as well as quality of life and outcomes addressing the causal pathway of interventions, such as pain barriers questionnaire for pain outcomes. We identified only one intervention focused on improving the efficiency and timeliness of care, in providing palliative radiotherapy. In terms of study design, results were generally consistent between RCTs and non-RCTs and between single-center and multi-center studies. In several instances, an initial non-RCT or single-center RCT was followed by a larger multicenter RCT, and results were generally consistent in the higher-quality studies.

Because of the diversity of the literature and outcomes, we were unable to draw conclusions about the influence of context (United States versus other), although studies of many effective interventions were conducted in the U.S. We also could not evaluate other context issues such as year of publication, or other organizational characteristics such as hospital size. A significant percentage of studies across the targets were multicenter studies. Descriptions of the context-sensitivity of interventions were minimal in the published studies. Time to followup was often short because of the severity of illness in included patient populations. Few studies evaluated followup at multiple time points, and for those who did, the results were often not consistent between time points (although sample sizes in these studies were often relatively small).

Details of the impact of implementation strategies were often absent or minimally reported, although a number of studies not evaluating effectiveness did report on implementation issues, such as challenges with recruitment and retention or low provider uptake of interventions. Many interventions did report on intermediate outcomes to help explain the causal pathway of the intervention, by using pain barriers questionnaires to assess the effectiveness of pain education interventions or measuring physician-provider communication about symptoms in studies evaluating facilitated relay of clinical data to providers.

## Clinical Context and Applicability of Evidence for Decisionmaking

For the four key targets, we found moderate strength of evidence for at least one key outcome for all but distress. For continuity, although studies were relatively diverse, evidence supports the use of interventions with patient-centered components; strength of evidence was moderate for the outcome of satisfaction. Many studies measured multiple outcomes and results were not consistent across outcomes (e.g., significant results for health care utilization but not for patient satisfaction). However, we found several well-conducted, high- and medium-quality studies that found statistically significant improvements of the intervention compared to the control group across multiple patient-centered outcomes, such as an RCT of outpatient palliative care for lung cancer64 and an RCT of facilitating hospice referrals for eligible nursing home patients.54 These studies can serve as potential models for translation elsewhere. For pain, strength of evidence was moderate and almost entirely limited to cancer and patient-centered interventions, We found moderate strength of evidence that communication and decisionmaking interventions, including structured family meetings and palliative care and ethics consultations, can impact health care utilization. However, studies were mostly limited to the intensive care unit setting, and applicability to other settings is unclear. It is important to note that interventions were classified and analyzed by target, and therefore this report will be best used by first deciding what target is the focus, and then reviewing the strength of evidence for different outcomes, and reviewing the different intervention and quality improvement types that were used.

We found evidence for effectiveness of certain quality improvement strategies in palliative care, and consultative models were more likely to be effective than those of integrative ones. For pain, nurse-led patient and family caregiver-directed educational interventions demonstrated some improved outcomes; however, half of the included studies focusing on this quality improvement type showed no significant reduction in pain scores. Although only three studies out of the 19 included studies focused specifically on provider behavior (application of a pain management algorithm,91 the use of strong opioids as first-line therapy,89 and a serial trial intervention to assess patients' unmet needs85), all found significant improvements in patient pain levels. Overall, due to the diversity of interventions included in this review, it is difficult to conclude what types of interventions are the most effective at reducing patient pain levels for patients with advanced and serious illness. Based on this review, no evidence exists about the effectiveness of other types of quality improvement, such as provider reminder systems or financial incentives, on improving patient pain outcomes. For distress, one study of psychosocial screening combined with triage to appropriate services showed evidence of effectiveness. For facilitated relay of clinical data, mainly use of quality of life questionnaires in outpatient oncology, evidence for effectiveness was weak. For other quality improvement types, and for the hospice setting, the number of studies was too small to draw conclusions. For the comparison between integrative, consultative, and combined models of palliative care, there were few combined studies. However, high- and medium-quality studies with strong evidence of effectiveness were found for both integrative and consultative models of care.

Few studies were found in the hospice and nursing home setting. Most studies focused on cancer patients, and only one study addressed pediatrics (in the neonatal intensive care unit), which limits applicability of this evidence to other populations.

## Limitations of the Review Process

Although our focus on studies only meeting a definition of quality improvement, and our including or separately reporting results for patients with advanced or life-threatening illness, improves the applicability of the results, many types of studies were not included in this review, particularly those that did not focus on patients with very advanced or serious disease (only 96 studies were included in this review from a much larger literature). The definition that we developed, studies with a majority of patients with advanced or serious illness, was sometimes challenging to apply to studies because illness characteristics were not reported in detail, and also may have excluded some studies including some relevant populations. For example, we found that many studies, such as an evaluation of telecare management for pain and depression, included a majority of patients who were cancer survivors or had early-stage disease157 or did not report the percentage of the population with advanced disease. In addition, although 25 percent of patients end their life in a nursing home, general nursing home populations would not have met the definition for “a majority of patients with advanced or serious illness” and studies in these populations were excluded.

This was also an issue for distress, where many interventions addressed general cancer populations or early-stage rather than advanced-stage disease. Few of these studies reported results for end-stage disease separately, so that we could abstract results; abstracting results for the whole population would have limited applicability, since patients' needs at different stages of illness may vary markedly. Many of these areas where we provided a more focused review and excluded studies have been well-addressed in other systematic reviews in broader populations, such as pain management in nursing homes,38 broader cancer pain interventions,27 and studies addressing broader populations for communication in the intensive care unit.34 For pain management, most included studies were patient- and caregiver-oriented interventions targeting this population specifically through study inclusion criteria and recruitment. This is due primarily to the fact that most institutional studies (e.g., in a hospital unit or entire nursing home) addressed broader populations or did not report results separately for advanced disease. Most advance care planning studies were excluded because they did not fit the definition of quality improvement (i.e., studies linked to the health care system and including an element of system change); and most studies to improve rates of care planning were in populations that did not fit our definition, such as general primary care or nursing home populations.

Our focus on studies only with prospective components also excluded some relevant studies and quality improvement types. The inclusion criteria for patient-centered outcomes also excluded studies focusing only on intermediate or indirect outcomes such as quantity of communication or provider assessments of quality of care. These exclusion criteria limited the inclusion of most studies of regulatory or policy interventions, which usually were retrospective or did not include patient-centered outcomes, such as the Physicians Orders for Life-Sustaining Treatment in the United States, or the Gold Standards Framework in the United Kingdom. Although these exclusions did limit the scope of the review somewhat, they also improved the applicability by including only higher-quality studies with direct patient- or family caregiver-related outcomes. Due to our focus on clinical outcomes, we also did not address the issue of costs. The inclusion criteria for published, peer-reviewed evaluations also limited the inclusion of the experience evaluating interventions in areas less linked to academic medical centers and the research community, such as hospice and social work interventions,158 and in areas that are less developed or where sample sizes are likely to be more limited, such as pediatrics.

We used a relatively broad definition of interventions to improve health care and quality improvement based on the original Closing the Quality Gap report, including studies conducted within or linked with the health care system and that have at least some element of system change. Palliative care consultation interventions, and interventions focusing on patient education and self-management, were included as part of this definition. Although these may not always be considered as quality improvement studies, they were included here because they are important methods for improving quality of care in patients with advanced and serious illness, particularly for pain management. Due to the diversity in the types of studies and the need to use one method for assessment of study quality across all studies, we used a risk of bias assessment tool for randomized trials, which did not capture many issues of methodologic quality within non-randomized quality improvement studies.

Finally, our focus on specific targets may have excluded some relevant studies, although we did include a variety of targets in the section on studies focusing on quality improvement. Included studies addressed a variety of targets, ranging from spirituality to timeliness and efficiency of care, with studies across all settings and in a variety of populations. Despite this focus, studies were still very heterogenous, and even descriptive synthesis across such different studies has limitations.

## Strengths and Limitations of the Literature

Although we identified a few high- and medium-quality studies with consistent findings within studies across outcomes, findings were often inconsistent among outcomes within the studies (e.g, statistically significant findings for health care utilization but not for satisfaction or symptoms) and many studies were of low quality or had methodological issues.54,64 RCTs are important in this field, and many of the highest-quality studies were RCTs, but since RCTs are often challenging or may not be the most appropriate study design for quality improvement interventions requiring institutional change, including the non-RCT literature was also important for this review. Common quality issues included small sample sizes, often due to insufficient recruitment, and lack of power for adequate statistical analysis. Even in many studies with adequate sample sizes, rates of recruitment were often low, reflecting the difficulty of conducting research in patients with advanced disease. Attrition was also a common issue, with a significant percentage of patients dying before the followup assessment or being unable to complete the assessment, even with short followup times for many studies (one month or less); studies with multiple points of followup often had insufficient sample sizes for later evaluations or found inconsistent results across time points.

Because of the diversity of interventions, outcomes, and reporting in the included studies, we judged that quantitative synthesis was not appropriate for any of the targets. Even for the target of pain (where all included studies evaluated pain as an outcome and 67 percent of the studies used the BPI to measure and report pain), due to the differential reporting (with concern for selective outcome reporting) of the BPI components (e.g. average pain, worst pain) and infrequent reporting of confidence intervals, as well as diversity of study interventions and populations, we judged that quantitative synthesis was not appropriate. We adapted the approach of quantifying the number of studies with statistically significant improvement with the intervention for each key outcome across studies that was used in most previous systematic reviews of this literature.

Many studies included outcomes not designed for advanced disease or end-of-life populations, which may have limited the effectiveness of evaluating the impact of interventions. Studies often reported many outcomes and did not designate primary outcomes, making interpretation of results difficult and diluting the impact of study outcomes (e.g., reporting on a long list of outcomes rather than focusing on those most likely to be impacted by the intervention). For example, no interventions in the target of continuity found an impact on overall symptom scores, although this was reported as an outcome for a significant percentage of studies. In addition, evidence for different outcomes were often inconsistent within interventions and targets. For example, for continuity, statistically significant differences were twice as common for patient satisfaction as for quality of life, a finding consistent with systematic reviews evaluating the pre-2000 studies in this field.15 Three of four studies that evaluated caregiver satisfaction showed a significant effect on this outcome, but none found an effect on caregiver burden, not even within the same study.

These findings could also be due to limitations in outcome measures or to the modifiability of some outcomes in patients with advanced disease. For example, although satisfaction, or reports of patient/caregiver experience, is an important metric that can integrate patient/caregiver experiences of health care, it is also challenging to measure in patients with advanced and serious illness. It is usually measured retrospectively, so previous care, grief, and suffering all influence ratings. Studies also used a variety of tools, many of which were not specifically developed for end-of-life populations. Finally, many studies in continuity and communication focused on the indirect outcome of health care utilization. While this outcome is important and clearly modifiable by interventions, these studies often did not measure or did not show similar effectiveness for patient-centered outcomes.

Finally, we identified a number of limitations in the reporting of studies, which made interpretation difficult in general and for the purposes of this review. Studies often did not clearly report study design or details on the intervention. Although we only included studies with comparison groups, many studies focused on differences within the intervention group in the reporting of outcomes, not the comparison of interest. Studies often did not report effect size or complete results, which did not allow for estimation of the magnitude of effect. Studies often did not report the percentage of patients with advanced disease, and few separated out outcomes in palliative care compared to other populations. Descriptions of interventions were often limited, difficult to interpret, and challenging to translate into the quality improvement types. Few studies identified theory or logic models; interventions often had not been well-evaluated in pilot studies identifying the most appropriate steps and outcomes, and often were not clearly developed based on existing literature. RCTs often did not report key elements, such as blinding or allocation, which lowered scores on risk of bias. Finally, studies often did not describe areas of context which might be helpful for understanding the strengths and limitations of settings and whether interventions could be replicated, such as local support for quality improvement, involvement of leadership, and funding and support for sustainability.

## Future Research

We identified several key areas for future research. Development of measurement instruments specific for this special population has improved since earlier systematic reviews8 in some domains, such as quality of life and satisfaction, and we did find moderate strength of evidence for satisfaction for the target of continuity and a few key studies found effectiveness for quality of life. However, the lack of overall effectiveness results, particularly for quality of life, indicates that further development of measurement instruments for some outcomes may be warranted. Well-developed instruments may still be lacking in some key areas, such as caregiver burden. In addition, few studies evaluated caregiver burden as an outcome; this is a critical area for seriously ill patients that requires further research. For areas where instruments are well-developed, such as pain, standards for outcome measures and for how they are reported would help future attempts to compare and synthesize the literature. In addition, similar outcomes were often used across targets but not necessarily customized to those targets; further research could better define how to best tailor an outcome such as satisfaction to a target or intervention type, or better understand interactions between different types of outcomes commonly used together such as quality of life and satisfaction.

We identified few published studies in the hospice setting, pediatric populations, or addressing the target of distress in this population, or any studies focusing on diverse populations or reducing disparities in outcomes, areas where there is significant need but challenges in developing and evaluating quality improvement interventions. Examples of disparities in end-of-life care that should be addressed include lower ratings by families of black and Hispanic patients on the quality of hospice care in the domains of emotional support, communication, and honoring patients' preferences. Although significant effort has focused on quality improvement in hospices in recent years, hospices have traditionally been relatively separated from researchers and often independent of academic connections, leading to the lack of published research. Few studies focused on specific non-cancer populations, such as patients with heart failure.

Particularly in some areas, there were few studies on specific types of quality improvement. Pain and distress management studies included mainly patient-centered intervention types. Few studies evaluated regulatory or policy interventions using patient-centered outcomes, few studies used quality improvement methodological approaches such as collaboratives, Plan-Do-Study-Act cycles, and audit and feedback, and few studies evaluated care across settings. No studies compared consultative to integrative intervention approaches. Finally, we identified several high- and medium quality studies using specific types of interventions with significant results across several outcomes, that would benefit from replication, evaluations of dissemination, methods of implementation, and effectiveness in different settings.54,64

## Conclusions

In conclusion, we found the most consistent evidence in a large number of studies, including several high- and medium-quality studies, for the effectiveness of interventions targeting continuity for the outcome of patient satisfaction; targeting pain using patient-centered interventions; targeting communication and decisionmaking on health care utilization outcomes in the intensive care unit setting. A quality improvement taxonomy fit relatively well in this field of research with some modifications, including the addition of the integrative-consultative model framework for the target of communication and decisionmaking. The evidence has multiple gaps, including studies in illnesses other than cancer for symptom management; pediatric populations and hospice settings; and addressing diverse populations and disparities in care. Methods to achieve adequate retention and recruitment, and appropriate targeting of outcome measures to interventions and development and selection of the most appropriate measurement tools, are also needed to maximize the value of these studies. Finally, studies evaluating the impact of policy changes on patient outcomes are needed. This review provides a basis for researchers to understand which study methods, quality improvement types, and elements of interventions are best supported by current evidence, and for clinicians, quality improvement staff, and policymakers to conclude how best to target evidence-based efforts to improve the quality of care for patients with advanced and serious illness. Importantly, some key issues of health care for the seriously ill and dying, such as care across settings and existential, psychosocial, and caregiving issues are challenging to address in this type of research. More coordinated initiatives, across multiple settings and providers and following patient populations over longer periods of time, will be needed to better understand how best to improve care for patients with advanced and serious illness.