# Appendix F Evidence Grading: Hospice and Nursing Homes

Table 1 Evidence grading for hospice and nursing home settings

Number of studies; subjects | Domains pertaining to strength of evidence | | | | Magnitude of effect and strength of evidence
| Risk of bias: | Consistency | Directness for outcome | Precision; Study heterogeneity | Absolute risk difference per 100 patients
Patient symptoms | | | | | Low SOE
4;1675 | RCTmedium | Inconsistent | Direct | Not applicable; medium | Improvement with intervention; low
1; 176 | Non-RCTmedium | Inconsistent | Direct | Not applicable; medium | Improvement with intervention; low
Utilization | | | | | Low SOE
2;1338 | RCTmedium | Consistent | Indirect | Not applicable; medium | Improvement with intervention; low
2;895 | Non-RCTmedium | Consistent | Indirect | Not applicable; medium | Improvement with intervention; low