# Appendix E Evidence Tables

Evidence Table 1 Population and study characteristics of all included studies

Evidence Table 2 Description of interventions for studies addressing continuity, coordination of care, and transitions

Evidence Table 3 Description of quality improvement elements in studies addressing continuity, coordination of care, and transitions

Evidence Table 4 Risk of bias assessment of studies addressing continuity, coordination of care, and transitions

Evidence Table 5 Outcomes reported in studies addressing continuity, coordination of care, and transitions

Evidence Table 6 Description of interventions for studies addressing pain

Evidence Table 7 Description of quality improvement elements in studies addressing pain

Evidence Table 8 Risk of bias assessment of studies addressing pain

Evidence Table 9 Outcomes reported in studies addressing pain

Evidence Table 10 Description of interventions for studies addressing distress

Evidence Table 11 Description of quality improvement elements in studies addressing distress

Evidence Table 12 Risk of bias assessment of studies addressing distress

Evidence Table 13 Outcomes reported in studies addressing distress

Evidence Table 14 Description of interventions for studies addressing communication

Evidence Table 15 Description of quality improvement elements in studies addressing communication

Evidence Table 16 Risk of bias assessment of studies addressing communication

Evidence Table 17 Outcomes reported in studies addressing communication

Evidence Table 18 Description of interventions for studies addressing quality improvement

Evidence Table 19 Description of quality improvement elements in studies addressing quality improvement

Evidence Table 20 Risk of bias assessment of studies addressing quality improvement

Evidence Table 21 Outcomes reported in studies addressing quality improvement