# Appendix D Excluded Articles

## Does Not Address a Palliative Care Intervention or Population

(2009). A Nurse Delivered Management Programme for Depression in People With Cancer Reduces Depressive Symptoms Compared With Usual Care. Evidence-Based Mental Health.
Acton GJ, Kang J. (2001). Interventions to reduce the burden of caregiving for an adult with dementia: a meta-analysis. Res Nurs Health.
Adegbehingbe OO, Akinyoola AL, Ariyibi AL, Oginni LM. (2009). Direct integration of government funding and family support for musculoskeletal tumor care in a resource-constrained country. Oncology.
Alexander BJ, Plank P, Carlson MB, Hanson P, Picken K, Schwebke K. (2005). Methods of pain assessment in residents of long-term care facilities: a pilot study. J Am Med Dir Assoc.
Allen RS, Allen JY, Hilgeman MM, DeCoster J. (2008). End-of-life decision-making, decisional conflict, and enhanced information: race effects. J Am Geriatr Soc.
Andersen BL, Farrar WB, Golden-Kreutz DM, Glaser R, Emery CF, Crespin TR, Shapiro CL, Carson WE. (2004). Psychological, behavioral, and immune changes after a psychological intervention: a clinical trial. J Clin Oncol.
Badger T, Segrin C, Meek P, Lopez AM, Bonham E, Sieger A. (2005). Telephone interpersonal counseling with women with breast cancer: symptom management and quality of life. Oncol Nurs Forum.
Baider L, Peretz T, Hadani PE, Koch U. (2001). Psychological intervention in cancer patients: a randomized study. General hospital psychiatry.
Barrio-Cantalejo IM, Molina-Ruiz A, Simon-Lorda P, Camara-Medina C, Toral Lopez I, del Mar Rodriguez del Aguila M, Bailon-Gomez RM. (2009). Advance directives and proxies' predictions about patients' treatment preferences. Nurs Ethics.
Berry DL, Blumenstein BA, Halpenny B, Wolpin S, Fann JR, Austin-Seymour M, Bush N, Karras BT, Lober WB, McCorkle R. (2011). Enhancing patient-provider communication with the electronic self-report assessment for cancer: a randomized trial. Journal of clinical oncology: official journal of the American Society of Clinical Oncology.
Boesen EH, Ross L, Frederiksen K, Thomsen BL, Dahlstrom K, Schmidt G, Naested J, Krag C, Johansen C. (2005). Psychoeducational intervention for patients with cutaneous malignant melanoma: a replication study. J Clin Oncol.
Bordeleau L, Szalai JP, Ennis M, Leszcz M, Speca M, Sela R, Doll R, Chochinov HM, Navarro M, Arnold A, Pritchard KI, Bezjak A, Llewellyn-Thomas HA, Sawka CA, Goodwin PJ. (2003). Quality of life in a randomized trial of group psychosocial support in metastatic breast cancer: overall effects of the intervention and an exploration of missing data. J Clin Oncol.
Boyes A, Newell S, Girgis A, McElduff P, Sanson-Fisher R. (2006). Does routine assessment and real-time feedback improve cancer patients' psychosocial well-being?. Eur J Cancer Care (Engl).
Bramsen I, van der Linden MH, Eskens FJ, Bijvank EM, van Groeningen CJ, Kaufman HJ, Aaronson NK. (2008). Evaluation of a face-to-face psychosocial screening intervention for cancer patients: acceptance and effects on quality of life. Patient Educ Couns.
Brown P, Clark MM, Atherton P, Huschka M, Sloan JA, Gamble G, Girardi J, Frost MH, Piderman K, Rummans TA. (2006). Will improvement in quality of life (QOL) impact fatigue in patients receiving radiation therapy for advanced cancer?. Am J Clin Oncol.
Brown RF, Butow PN, Dunn SM, Tattersall MH. (2001). Promoting patient participation and shortening cancer consultations: a randomised trial. Br J Cancer.
Brown RF, Butow PN, Sharrock MA, Henman M, Boyle F, Goldstein D, Tattersall MH. (2004). Education and role modelling for clinical decisions with female cancer patients. Health Expect.
Burgio KL, Goode PS, Urban DA, Umlauf MG, Locher JL, Bueschen A, Redden DT. (2006). Preoperative biofeedback assisted behavioral training to decrease post-prostatectomy incontinence: a randomized, controlled trial. J Urol.
Chan CL, Ho RT, Lee PW, Cheng JY, Leung PP, Foo W, Chow LW, Sham JS, Spiegel D. (2006). A randomized controlled trial of psychosocial interventions using the psychophysiological framework for Chinese breast cancer patients. Journal of psychosocial oncology.
Chang MC, Chang YC, Chiou JF, Tsou TS, Lin CC. (2002). Overcoming patient-related barriers to cancer pain management for home care patients. A pilot study. Cancer Nurs.
Chang PH, Lai YH, Shun SC, Lin LY, Chen ML, Yang Y, Tsai JC, Huang GS, Cheng SY. (2008). Effects of a Walking Intervention on Fatigue-Related Experiences of Hospitalized Acute Myelogenous Leukemia Patients Undergoing Chemotherapy: a Randomized Controlled Trial. Journal of Pain & Symptom Management.
Chung SK, Ahn MJ, Yoo JY, Choi M, Hyang N, Woo SR, Kim SS, Kim SA, Oh EG. (2011). Implementation of best practice for chemotherapy-induced nausea and vomiting in an acute care setting. Int J Evid Based Healthc.
Comley AL, DeMeyer E. (2001). Assessing patient satisfaction with pain management through a continuous quality improvement effort. J Pain Symptom Manage.
Cook AJ. (1998). Cognitive-behavioral pain management for elderly nursing home residents. The journals of gerontology. Series B, Psychological sciences and social sciences.
de la Porte PW, Lok DJ, van Veldhuisen DJ, van Wijngaarden J, Cornel JH, Zuithoff NP, Badings E, Hoes AW. (2007). Added value of a physician-and-nurse-directed heart failure clinic: results from the Deventer-Alkmaar heart failure study. Heart (British Cardiac Society).
Del Sindaco D, Pulignano G, Minardi G, Apostoli A, Guerrieri L, Rotoloni M, Petri G, Fabrizi L, Caroselli A, Venusti R, Chiantera A, Giulivi A, Giovannini E, Leggio F. (2007). Two-year outcome of a prospective, controlled study of a disease management programme for elderly patients with heart failure. Journal of cardiovascular medicine (Hagerstown, Md.).
Detering KM, Hancock AD, Reade MC, Silvester W. (2010). The impact of advance care planning on end of life care in elderly patients: randomised controlled trial. BMJ.
Dodd MJ, Cho MH, Miaskowski C, Painter PL, Paul SM, Cooper BA, Duda J, Krasnoff J, Bank KA. (2010). A randomized controlled trial of home-based exercise for cancer-related fatigue in women during and after chemotherapy with or without radiation therapy. Cancer Nurs.
Downe-Wamboldt BL, Butler LJ, Melanson PM, Coulter LA, Singleton JF, Keefe JM, Bell DG. (2007). The effects and expense of augmenting usual cancer clinic care with telephone problem-solving counseling. Cancer Nurs.
Dragone MA, Bush PJ, Jones JK, Bearison DJ, Kamani S. (2002). Development and evaluation of an interactive CD-ROM for children with leukemia and their families. Patient Educ Couns.
Dufault MA, Willey-Lessne C. J Nurs Care Qual.
Edmonds P, Hart S, Wei Gao, Vivat B, Burman R, Silber E, Higginson IJ. (2010). Palliative care for people severely affected by multiple sclerosis: evaluation of a novel palliative care service. Mult Scler.
Edwards AG, Hailey S, Maxwell M, Fairchild A, Pituskin E, Rose B, Ghosh S, Dutka J, Driga A, Tachynski P, Borschneck J, Gagnon L, Macdonnell S, Middleton J, Thavone K, Carstairs S, Brent D, Severin D. (2004). Psychological interventions for women with metastatic breast cancer: The rapid access palliative radiotherapy program: blueprint for initiation of a one-stop multidisciplinary bone metastases clinic. Cochrane Database Syst Rev: Support Care Cancer.
El-Jawahri A, Podgurski LM, Eichler AF, Plotkin SR, Temel JS, Mitchell SL, Chang Y, Barry MJ, Volandes AE. (2010). Use of video to facilitate end-of-life discussions with patients with cancer: a randomized controlled trial. J Clin Oncol.
Ell K, Xie B, Quon B, Quinn DI, Dwight-Johnson M, Lee PJ. (2008). Randomized controlled trial of collaborative care management of depression among low-income patients with cancer. J Clin Oncol.
Fann JR, Fan MY, Unutzer J. (2009). Improving primary care for older adults with cancer and depression. J Gen Intern Med.
Fisher Susan E. (2007). A Pain Assessment and Communication Training Intervention to Improve Detection of Behavioral Pain Cues and Pain Management Communication Among Direct-Care Staff in the Nursing Home. Dissertation Abstracts International: Section B: the Sciences and Engineering.
Forchuk C. (2009). A Nurse-Delivered Intervention Was Effective for Depression in Patients With Cancer. Evidence-Based Nursing.
Franck LS, Allen A, Oulton K. (2007). Making pain assessment more accessible to children and parents: can greater involvement improve the quality of care?. The Clinical journal of pain.
Geller MA, Downs LS, Judson PL, Ghebre R, Argenta PA, Carson LF, Jonson AL, Godfrey K, Vogel RI, Petzel SV. (2010). Learning about ovarian cancer at the time of diagnosis: video versus usual care. Gynecol Oncol.
Giesler RB, Given B, Given CW, Rawl S, Monahan P, Burns D, Azzouz F, Reuille KM, Weinrich S, Koch M, Champion V. (2005). Improving the quality of life of patients with prostate carcinoma: a randomized trial testing the efficacy of a nurse-driven intervention. Cancer.
Girgis A, Breen S, Stacey F, Lecathelinais C. (2009). Impact of two supportive care interventions on anxiety, depression, quality of life, and unmet needs in patients with nonlocalized breast and colorectal cancers. J Clin Oncol.
Given B, Given CW, Sikorskii A, Jeon S, Sherwood P, Rahbar M. (2006). The Impact of Providing Symptom Management Assistance on Caregiver Reaction: Results of a Randomized Trial. Journal of Pain & Symptom Management.
Given C, Given B, Rahbar M, Jeon S, McCorkle R, Cimprich B, Galecki A, Kozachik S, Devoss D, Brady A, Fisher-Malloy MJ, Courtney K, Bowie E. (2004). Does a symptom management intervention affect depression among cancer patients: results from a clinical trial. Psychooncology.
Goerling U, Foerg A, Sander S, Schramm N, Schlag PM. (2011). The impact of short-term psycho-oncological interventions on the psychological outcome of cancer patients of a surgical-oncology department a randomised controlled study. Eur J Cancer.
Gotay CC, Moinpour CM, Unger JM, Jiang CS, Coleman D, Martino S, Parker BJ, Bearden JD, Dakhil S, Gross HM, Lippman S, Albain KS. (2007). Impact of a peer-delivered telephone intervention for women experiencing a breast cancer recurrence. J Clin Oncol.
Grassi L, Rossi E, Caruso R, Nanni MG, Pedrazzi S, Sofritti S, Sabato S. (2011). Educational intervention in cancer outpatient clinics on routine screening for emotional distress: an observational study. Psychooncology.
Graves KD, Carter CL, Anderson ES, Winett RA. (2003). Quality of life pilot intervention for breast cancer patients: use of social cognitive theory. Palliat Support Care.
Grimaldo DA, Wiener-Kronish JP, Jurson T, Shaughnessy TE, Curtis JR, Liu LL. (2001). A randomized, controlled trial of advanced care planning discussions during preoperative evaluations. Anesthesiology.
Gysels M, Higginson IJ. (2007). Interactive technologies and videotapes for patient education in cancer care: systematic review and meta-analysis of randomised trials. Support Care Cancer.
Hendrix CC, Landerman R, Abernethy AP. (2011). Effects of an Individualized Caregiver Training Intervention on Self-Efficacy of Cancer Caregivers. West J Nurs Res.
Hermiz O, Comino E, Marks G, Daffurn K, Wilson S, Harris M. (2002). Randomised controlled trial of home based care of patients with chronic obstructive pulmonary disease. BMJ (Clinical research ed.).
Hersch J, Juraskova I, Price M, Mullan B. (2009). Psychosocial interventions and quality of life in gynaecological cancer patients: a systematic review. Psychooncology.
Heyn L, Finset A, Eide H, Ruland CM. (2011). Effects of an interactive tailored patient assessment on patient-clinician communication in cancer care. Psychooncology.
Higginson IJ, McCrone P, Hart SR, Burman R, Silber E, Edmonds PM. (2009). Is short-term palliative care cost-effective in multiple sclerosis? A randomized phase II trial. J Pain Symptom Manage.
Hilarius DL, Kloeg PH, Gundy CM, Aaronson NK. (2008). Use of health-related quality-of-life assessments in daily clinical oncology nursing practice: a community hospital-based intervention study. Cancer.
Hinds PS. (2000). Fostering coping by adolescents with newly diagnosed cancer. Semin Oncol Nurs.
Hogan DB, Fox RA. (1990). A prospective controlled trial of a geriatric consultation team in an acute-care hospital. Age and ageing.
Hulsman RL, Ros WJ, Winnubst JA, Bensing JM. (2002). The effectiveness of a computer-assisted instruction programme on communication skills of medical specialists in oncology. Med Educ.
Husebo BS, Ballard C, Aarsland D. (2011). Pain treatment of agitation in patients with dementia: a systematic review. Int J Geriatr Psychiatry.
Husebo BS, Ballard C, Sandvik R, Nilsen OB, Aarsland D. (2011). Efficacy of treating pain to reduce behavioural disturbances in residents of nursing homes with dementia: cluster randomised clinical trial. BMJ.
Ibfelt E, Rottmann N, Kjaer T, Hoybye MT, Ross L, Frederiksen K, Johansen C, Dalton SO. (2011). No change in health behavior, BMI or self-rated health after a psychosocial cancer rehabilitation: Results of a randomized trial. Acta Oncol.
Idell CS, Grant M, Kirk C. (2007). Alignment of pain reassessment practices and National Comprehensive Cancer Network guidelines. Oncol Nurs Forum.
Jaarsma T, Halfens R, Tan F, Abu-Saad HH, Dracup K, Diederiks J. (2000). Self-care and quality of life in patients with advanced heart failure: the effect of a supportive educational intervention. Heart & lung: the journal of critical care.
Johansson B, Brandberg Y, Hellbom M, Persson C, Petersson LM, Berglund G, Glimelius B. (2008). Health-related quality of life and distress in cancer patients: results from a large randomised study. Br J Cancer.
Johansson B, Holmberg L, Berglund G, Brandberg Y, Hellbom M, Persson C, Glimelius B, Sjoden PO. (2001). Reduced utilisation of specialist care among elderly cancer patients: a randomised study of a primary healthcare intervention. Eur J Cancer.
Jones KR, Fink R, Vojir C, Pepper G, Hutt E, Clark L, Scott J, Martinez R, Vincent D, Mellis BK. (2004). Translation research in long-term care: improving pain management in nursing homes. Worldviews Evid Based Nurs.
Jones K. (2006). Effective pain management: lessons from a nursing home research study. J Healthc Qual.
Jones L, Harrington J, Barlow CA, Tookman A, Drake R, Barnes K, King M. (2011). Advance care planning in advanced cancer: Can it be achieved? An exploratory randomized patient preference trial of a care planning discussion. Palliat Support Care.
Kaasalainen Sharon, Brazil Kevin, Coker Esther, Ploeg Jenny, Martin-Misener Ruth, Donald Faith, Dicenso Alba, Hadjistavropoulos Thomas, Dolovich Lisa, Papaioannou Alexandra, Emili Anna, Burns TIM. (2010). An Action-Based Approach to Improving Pain Management in Long-Term Care. Canadian Journal on Aging.
Kirchhoff KT, Hammes BJ, Kehl KA, Briggs LA, Brown RL. (2010). Effect of a disease-specific planning intervention on surrogate understanding of patient goals for future medical treatment. J Am Geriatr Soc.
Klosky JL, Garces-Webb DM, Buscemi J, Schum L, Tyc VL, Merchant TE. (2007). Examination of an interactive-educational intervention in improving parent and child distress outcomes associated with pediatric radiation therapy procedures. Children's Health Care.
Klosky JL, Tyc VL, Srivastava DK, Tong X, Kronenberg M, Booker ZJ, de Armendi AJ, Merchant TE. (2004). Brief report: Evaluation of an interactive intervention designed to reduce pediatric distress during radiation therapy procedures. J Pediatr Psychol.
Kolarik RC, Arnold RM, Fischer GS, Hanusa BH. (2002). Advance care planning. J Gen Intern Med.
Kravitz Richard L, Tancredi Daniel J, Grennan Tim, Kalauokalani Donna, Street Richard L, Slee Christina K, Wun Ted, Oliver Jennifer Wright, Lorig Kate, Franks Peter. (2011). Cancer Health Empowerment for Living without Pain (Ca-HELP): Effects of a tailored education and coaching intervention on pain and impairment. Pain.
Kressel LM, Chapman GB. (2007). The default effect in end-of-life medical treatment preferences. Med Decis Making.
Kristeller JL, Rhodes M, Cripe LD, Sheets V. (2005). Oncologist Assisted Spiritual Intervention Study (OASIS): patient acceptability and initial evidence of effects. Int J Psychiatry Med.
Kroenke K, Theobald D, Wu J, Norton K, Morrison G, Carpenter J, Tu W. (2010). Effect of telecare management on pain and depression in patients with cancer: a randomized trial. JAMA.
Kurtz ME, Kurtz JC, Given CW, Given B. (2005). A randomized, controlled trial of a patientcaregiver symptom control intervention: effects on depressive symptomatology of caregivers of cancer patients. J Pain Symptom Manage.
Lai YH, Guo SL, Keefe FJ, Tsai SL, Chien CC, Sung YC, Chen ML. (2004). Effects of brief pain education on hospitalized cancer patients with moderate to severe pain. Support Care Cancer.
LaMantia MA, Scheunemann LP, Viera AJ, Busby-Whitehead J, Hanson LC. (2010). Interventions to improve transitional care between nursing homes and hospitals: a systematic review. J Am Geriatr Soc.
Lecouturier J, Crack L, Mannix K, Hall RH, Bond S. (2002). Evaluation of a patient-held record for patients with cancer. Eur J Cancer Care (Engl).
Liu LN, Li CY, Tang ST, Huang CS, Chiou AF. (2006). Role of continuing supportive cares in increasing social support and reducing perceived uncertainty among women with newly diagnosed breast cancer in Taiwan. Cancer Nurs.
Long C, Morgan BM, Alonzo TR, Mitchell KM, Bonnell DK, Beardsley ME. (2010). Improving Pain Management in Long-Term Care: the Campaign Against Pain. Journal of Hospice & Palliative Nursing.
Macvean ML, White VM, Pratt S, Grogan S, Sanson-Fisher R. (2007). Reducing the unmet needs of patients with colorectal cancer: a feasibility study of The Pathfinder Volunteer Program. Support Care Cancer.
Manne SL, Rubin S, Edelson M, Rosenblum N, Bergman C, Hernandez E, Carlson J, Rocereto T, Winkel G. (2007). Coping and communication-enhancing intervention versus supportive counseling for women diagnosed with gynecological cancers. J Consult Clin Psychol.
Manne SL, Winkel G, Rubin S, Edelson M, Rosenblum N, Bergman C, Hernandez E, Carlson J, Rocereto T. (2008). Mediators of a coping and communication-enhancing intervention and a supportive counseling intervention among women diagnosed with gynecological cancers. J Consult Clin Psychol.
Martin-Carrasco M, Martin MF, Valero CP, Millan PR, Garcia CI, Montalban SR, Vazquez ALG, Piris SP, Vilanova MB. (2009). Effectiveness of a psychoeducation intervention program in the reduction of caregiver burden in Alzheimer's Disease patients' caregivers. International Journal of Geriatric Psychiatry.
McCann L, Maguire R, Miller M, Kearney N. (2009). Patients' perceptions and experiences of using a mobile phone-based advanced symptom management system (ASyMS) to monitor and manage chemotherapy related toxicity. Eur J Cancer Care (Engl).
McCorkle R, Dowd M, Ercolano E, Schulman-Green D, Williams AL, Siefert ML, Steiner J, Schwartz P. (2009). Effects of a nursing intervention on quality of life outcomes in post-surgical women with gynecological cancers. Psychooncology.
McLachlan SA, Allenby A, Matthews J, Wirth A, Kissane D, Bishop M, Beresford J, Zalcberg J. (2001). Randomized trial of coordinated psychosocial interventions based on patient self-assessments versus standard care to improve the psychosocial functioning of patients with cancer. J Clin Oncol.
Morrison RS, Chichin E, Carter J, Burack O, Lantz M, Meier DE. (2005). The effect of a social work intervention to enhance advance care planning documentation in the nursing home. J Am Geriatr Soc.
Morrison RS, Chichin E, Carter J, Burack O, Lantz M, Meier DE. (2005). The effect of a social work intervention to enhance advance care planning documentation in the nursing home. Journal of the American Geriatrics Society.
Morrison RS, Meier DE, Fischberg D, Moore C, Degenholtz H, Litke A, Maroney-Galin C, Siu AL. (2006). Improving the management of pain in hospitalized adults. Arch Intern Med.
Naylor MD, Brooten D, Campbell R, Jacobsen BS, Mezey MD, Pauly MV, Schwartz JS. (1999). Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA: the journal of the American Medical Association.
Nural N, Hintistan S, Gursoy AA, Duman EN. (2009). The effect of home healthcare on quality of life in patients diagnosed with gastrointestinal cancer. Gastroenterol Nurs.
O'Brien MA, Whelan TJ, Villasis-Keever M, Gafni A, Charles C, Roberts R, Schiff S, Cai W. (2009). Are cancer-related decision aids effective? A systematic review and meta-analysis. J Clin Oncol.
Oeseburg B, Wynia K, Middel B, Reijneveld SA. (2009). Effects of case management for frail older people or those with chronic illness: a systematic review. Nurs Res.
Oh PJ, Kim SH. (2010). Effects of a brief psychosocial intervention in patients with cancer receiving adjuvant therapy. Oncol Nurs Forum.
Oleske DM, Hauck WW. (1988). A population-based evaluation of the impact of interventions for improving care to cancer patients in the home setting. Home Health Care Services Quarterly.
Oliver DP, Bickel-Swenson D, Zweig S, Kruse R, Mehr D. (2009). Experience with implementation of a quality improvement project for the care of nursing home residents. J Nurs Care Qual.
Park CS, Yoo YS, Choi DW, Park HJ, Kim JI. (2011). Journal of Korean Academy of Nursing.
Pearlman RA, Starks H, Cain KC, Cole WG. (2005). Improvements in advance care planning in the Veterans Affairs System: results of a multifaceted intervention. Arch Intern Med.
Penrod JD, Luhrs CA, Livote EE, Cortez TB, Kwak J. (2011). Implementation and evaluation of a network-based pilot program to improve palliative care in the intensive care unit. J Pain Symptom Manage.
Pruyn JF, Heule-Dieleman HA, Knegt PP, Mosterd FR, van Hest MA, Sinnige HA, Pruyn AT, de Boer MF. (2004). On the enhancement of efficiency in care for cancer patients in outpatient clinics: an instrument to accelerate psychosocial screening and referral. Patient Educ Couns.
Rao AV, Hsieh F, Feussner JR, Cohen HJ. (2005). Geriatric evaluation and management units in the care of the frail elderly cancer patient. J Gerontol A Biol Sci Med Sci.
Rask MT, Jensen ML, Andersen J, Zachariae R. (2009). Effects of an intervention aimed at improving nurse-patient communication in an oncology outpatient clinic. Cancer Nurs.
Razavi D, Merckaert I, Marchal S, Libert Y, Conradt S, Boniver J, Etienne AM, Fontaine O, Janne P, Klastersky J, Reynaert C, Scalliet P, Slachmuylder JL, Delvaux N. (2003). How to optimize physicians' communication skills in cancer care: results of a randomized study assessing the usefulness of posttraining consolidation workshops. J Clin Oncol.
Resnick B, Quinn C, Baxter S. (2004). Testing the feasibility of implementation of clinical practice guidelines in long-term care facilities. J Am Med Dir Assoc.
Rodin G, Lloyd N, Katz M, Green E, Mackay JA, Wong RK. (2007). The treatment of depression in cancer patients: a systematic review. Support Care Cancer.
Ross L, Thomsen BL, Karlsen RV, Boesen EH, Johansen C. (2005). A randomized psychosocial intervention study on the effect of home visits on the well-being of Danish colorectal cancer patients--the INCA Project. Psychooncology.
Rottmann N, Dalton SO, Bidstrup PE, Wurtzen H, Hoybye MT, Ross L, Christensen J, Frederiksen K, Hansen DG, Johansen C. (2011). No improvement in distress and quality of life following psychosocial cancer rehabilitation. A randomised trial. Psychooncology.
Sahler OJ, Fairclough DL, Phipps S, Mulhern RK, Dolgin MJ, Noll RB, Katz ER, Varni JW, Copeland DR, Butler RW. (2005). Using problem-solving skills training to reduce negative affectivity in mothers of children with newly diagnosed cancer: report of a multisite randomized trial. J Consult Clin Psychol.
Sandgren AK, McCaul KD. (2007). Long-term telephone therapy outcomes for breast cancer patients. Psychooncology.
Schou I, Ekeberg O, Karesen R, Sorensen E. (2008). Psychosocial intervention as a component of routine breast cancer care-who participates and does it help?. Psychooncology.
Schwartz CE, Wheeler HB, Hammes B, Basque N, Edmunds J, Reed G, Ma Y, Li L, Tabloski P, Yanko J. (2002). Early intervention in planning end-of-life care with ambulatory geriatric patients: results of a pilot trial. Arch Intern Med.
Scott JT, Entwistle VA, Sowden AJ, Watt I. (2001). Communicating with children and adolescents about their cancer. Cochrane Database Syst Rev.
Scott JT, Harmsen M, Prictor MJ, Sowden AJ, Watt I. (2003). Interventions for improving communication with children and adolescents about their cancer. Cochrane Database Syst Rev.
Shell JA. (2002). Evidence-based practice for symptom management in adults with cancer: sexual dysfunction. Oncol Nurs Forum.
Shelton W, Moore CD, Socaris S, Gao J, Dowling J. (2010). The effect of a family support intervention on family satisfaction, length-of-stay, and cost of care in the intensive care unit. Crit Care Med.
Shojania KG, Duncan BW, McDonald KM, Wachter RM, Markowitz AJ. (2001). Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ).
Silliman RA, McGarvey ST, Raymond PM, Fretwell MD. (1990). The Senior Care Study. Does inpatient interdisciplinary geriatric assessment help the family caregivers of acutely ill older patients?. Journal of the American Geriatrics Society.
Smith MY, DuHamel KN, Egert J, Winkel G. (2010). Impact of a brief intervention on patient communication and barriers to pain management: results from a randomized controlled trial. Patient Educ Couns.
Song MK, Donovan HS, Piraino BM, Choi J, Bernardini J, Verosky D, Ward SE. (2010). Effects of an intervention to improve communication about end-of-life care among African Americans with chronic kidney disease. Appl Nurs Res.
Song MK. (2004). Effects of end-of-life discussions on patients' affective outcomes. Nurs Outlook.
Steel A, Underwood C, Notley C, Blunt M. (2008). The impact of offering a relatives' clinic on the satisfaction of the next-of-kin of critical care patients-a prospective time-interrupted trial. Intensive Crit Care Nurs.
Stehl ML, Kazak AE, Alderfer MA, Rodriguez A, Hwang WT, Pai ALH, Boeving A, Reilly A. (2009). Conducting a randomized clinical trial of an psychological intervention for parentscaregivers of children with cancer shortly after diagnosis. Journal of Pediatric Psychology.
Stevenson KM, Dahl JL, Berry PH, Beck SL, Griffie J. (2006). Institutionalizing effective pain management practices: practice change programs to improve the quality of pain management in small health care organizations. J Pain Symptom Manage.
Strong V, Waters R, Hibberd C, Murray G, Wall L, Walker J, McHugh G, Walker A, Sharpe M. (2008). Management of depression for people with cancer (SMaRT oncology 1): a randomised trial. Lancet.
Swafford KL, Miller LL, Tsai PF, Herr KA, Ersek M. (2009). Improving the process of pain care in nursing homes: a literature synthesis. J Am Geriatr Soc.
Tulipani C, Morelli F, Spedicato MR, Maiello E, Todarello O, Porcelli P. (2010). Alexithymia and cancer pain: the effect of psychological intervention. Psychother Psychosom.
Walker MS, Podbilewicz-Schuller Y. (2005). Video preparation for breast cancer treatment planning: results of a randomized clinical trial. Psycho-oncology.
Wessels H, de Graeff A, Groenewegen G, Wynia K, de Heus M, Vos JB, Tjia P, Kruitwagen CL, Teunissen SC, Voest EE. (2010). Impact of integration of clinical and outpatient units on cancer patient satisfaction. Int J Qual Health Care.
Wilkinson OM, Duncan-Skingle F, Pryor JA, Hodson ME. (2008). A feasibility study of home telemedicine for patients with cystic fibrosis awaiting transplantation. Journal of telemedicine and telecare.
Williams JG, Cheung WY, Chetwynd N, Cohen DR, El-Sharkawi S, Finlay I, Lervy B, Longo M, Malinovszky K. (2001). Pragmatic randomised trial to evaluate the use of patient held records for the continuing care of patients with cancer. Qual Health Care.
Wong FK, Chow SK, Chan TM. (2010). Evaluation of a nurse-led disease management programme for chronic kidney disease: a randomized controlled trial. International journal of nursing studies.
Yates P, Edwards H, Nash R, Aranda S, Purdie D, Najman J, Skerman H, Walsh A. (2004). A randomized controlled trial of a nurse-administered educational intervention for improving cancer pain management in ambulatory settings. Patient education and counseling.
Young J, Harrison J, Solomon M, Butow P, Dennis R, Robson D, Auld S. (2010). Development and feasibility assessment of telephone-delivered supportive care to improve outcomes for patients with colorectal cancer: pilot study of the CONNECT intervention. Support Care Cancer.
Zernikow B, Hasan C, Hechler T, Huebner B, Gordon D, Michel E. (2008). Stop the Pain! A Nation-Wide Quality Improvement Programme in Paediatric Oncology Pain Control. European Journal of Pain.

## Does Not Include Patient and Family-Centered Outcomes in the Results

Blackford J, Street A. (2011). Is an advance care planning model feasible in community palliative care? A multi-site action research approach. J Adv Nurs.
Bucher JA, Loscalzo M, Zabora J, Houts PS, Hooker C, BrintzenhofeSzoc K. (2001). Problem-solving cancer care education for patients and caregivers. Cancer Pract.
Chan R, Webster J. (2010). End-of-life care pathways for improving outcomes in caring for the dying. Cochrane Database Syst Rev.
Currow DC, Abernethy AP, Shelby-James TM, Phillips PA. (2006). The impact of conducting a regional palliative care clinical study. Palliative medicine.
Dale J, Petrova M, Munday D, Koistinen-Harris J, Lall R, Thomas K. (2009). A national facilitation project to improve primary palliative care: impact of the Gold Standards Framework on process and self-ratings of quality. Qual Saf Health Care.
Daly BJ. (2000). Organizational change and delivery of multidisciplinary palliative care. Respir Care.
Glajchen M, Lawson R, Homel P, Desandre P, Todd KH. (2011). A rapid two-stage screening protocol for palliative care in the emergency department: a quality improvement initiative. J Pain Symptom Manage.
Hall S, Chochinov H, Harding R, Murray S, Richardson A, Higginson IJ. (2009). A Phase II randomised controlled trial assessing the feasibility, acceptability and potential effectiveness of dignity therapy for older people in care homes: study protocol. BMC Geriatr.
Hall S, Edmonds P, Harding R, Chochinov H, Higginson IJ. (2009). Assessing the feasibility, acceptability and potential effectiveness of Dignity Therapy for people with advanced cancer referred to a hospital-based palliative care team: Study protocol. BMC Palliat Care.
Harris D, Hillier LM, Keat N. (2007). Sustainable practice improvements: impact of the Comprehensive Advanced Palliative Care Education (CAPCE) program. J Palliat Care.
Higginson IJ, Hart S, Burman R, Silber E, Saleem T, Edmonds P. (2008). Randomised controlled trial of a new palliative care service: Compliance, recruitment and completeness of follow-up. BMC Palliat Care.
Hill TE, Ginsburg M, Citko J, Cadogan M. (2005). Improving End-of-Life Care in Nursing Facilities: the Community State Partnership to Improve End-of-Life Care -California. Journal of Palliative Medicine.
Hoffmann W, Munzinger H, Horstkotte E, Greiser E. (2004). A population-based evaluation of an intervention to improve advanced stage cancer pain management. J Pain Symptom Manage.
Idell CS, Grant M, Kirk C. (2007). Alignment of pain reassessment practices and National Comprehensive Cancer Network guidelines. Oncol Nurs Forum.
Jones L, Harrington J, Barlow CA, Tookman A, Drake R, Barnes K, King M. (2011). Advance care planning in advanced cancer: Can it be achieved? An exploratory randomized patient preference trial of a care planning discussion. Palliat Support Care.
Kravitz RL, Tancredi DJ, Street RL, Kalauokalani D, Grennan T, Wun T, Slee C, Evans Dean D, Lewis L, Saito N, Franks P. (2009). Cancer Health Empowerment for Living without Pain (Ca-HELP): study design and rationale for a tailored education and coaching intervention to enhance care of cancer-related pain. BMC Cancer.
Kutner JS, Metcalfe T, Vu KO, Fink R, Nelson-Marten P, Armstrong JD, Seligman PA. (2004). Implementation of an ad hoc hospital-based palliative care consult service. J Pain Symptom Manage.
LaMantia MA, Scheunemann LP, Viera AJ, Busby-Whitehead J, Hanson LC. (2010). Interventions to improve transitional care between nursing homes and hospitals: a systematic review. J Am Geriatr Soc.
Laycock W. (2011). Think about it: a prompt to discuss end of life choices. Nurs Times.
Maguire P, Pitceathly C. (2003). Improving the psychological care of cancer patients and their relatives. The role of specialist nurses. J Psychosom Res.
Martin WE, Miller SC, Welch LC, Burrill J. (2007). Improving access to hospice: the Physician Feedback and Reminders to Improve Access to Hospice (PFRIAH) study. Med Health R I.
Meyers FJ, Linder J. (2003). Simultaneous care: disease treatment and palliative care throughout illness. J Clin Oncol.
Mularski RA, Curtis JR, Billings JA, Burt R, Byock I, Fuhrman C, Mosenthal AC, Medina J, Ray DE, Rubenfeld GD, Schneiderman LJ, Treece PD, Truog RD, Levy MM. (2006). Proposed quality measures for palliative care in the critically ill: a consensus from the Robert Wood Johnson Foundation Critical Care Workgroup. Crit Care Med.
Murray MA, Stacey D, Wilson KG, O'Connor AM. (2010). Skills training to support patients considering place of end-of-life care: a randomized control trial. Journal of palliative care.
Norton SA, Hogan LA, Holloway RG, Temkin-Greener H, Buckley MJ, Quill TE. (2007). Proactive palliative care in the medical intensive care unit: effects on length of stay for selected high-risk patients. Crit Care Med.
Puntillo KA, Mcadam JL. (2006). Communication Between Physicians and Nurses as a Target for Improving End-of-Life Care in the Intensive Care Unit: Challenges and Opportunities for Moving Forward. Critical Care Medicine.
Quill TE. (2004). Dying and decision making--evolution of end-of-life options. N Engl J Med.
Razavi D, Merckaert I, Marchal S, Libert Y, Conradt S, Boniver J, Etienne AM, Fontaine O, Janne P, Klastersky J, Reynaert C, Scalliet P, Slachmuylder JL, Delvaux N. (2003). How to optimize physicians' communication skills in cancer care: results of a randomized study assessing the usefulness of posttraining consolidation workshops. J Clin Oncol.
Schwartz CE, Wheeler HB, Hammes B, Basque N, Edmunds J, Reed G, Ma Y, Li L, Tabloski P, Yanko J. (2002). Early intervention in planning end-of-life care with ambulatory geriatric patients: results of a pilot trial. Arch Intern Med.
Shelby-James TM, Currow DC, Phillips PA, Williams H, Abernethy AP. (2007). Promoting patient centred palliative care through case conferencing. Aust Fam Physician.
Sihra L, Harris M, O'Reardon C. (2011). Using the improving palliative care in the intensive care unit (IPAL-ICU) project to promote palliative care consultation. J Pain Symptom Manage.
Silveira MJ, Given CW, Cease KB, Sikorskii A, Given B, Northouse LL, Piette JD. (2011). Cancer CarePartners: Improving patients' symptom management by engaging informal caregivers. BMC Palliat Care.
Sitzia J, Cotterell P, Richardson A. (2006). Interprofessional collaboration with service users in the development of cancer services: the Cancer Partnership Project. J Interprof Care.
Taplin SH, Rodgers AB. (2010). Toward improving the quality of cancer care: addressing the interfaces of primary and oncology-related subspecialty care. J Natl Cancer Inst Monogr.
Taplin SH, Clauser S, Rodgers AB, Breslau E, Rayson D. (2010). Interfaces across the cancer continuum offer opportunities to improve the process of care. J Natl Cancer Inst Monogr.
Thomas K, Noble B. (2007). Improving the delivery of palliative care in general practice: an evaluation of the first phase of the Gold Standards Framework. Palliat Med.
Treece PD, Engelberg RA, Crowley L, Chan JD, Rubenfeld GD, Steinberg KP, Curtis JR. (2004). Evaluation of a standardized order form for the withdrawal of life support in the intensive care unit. Crit Care Med.
Vallerand AH, Riley-Doucet C, Hasenau SM, Templin T. (2004). Improving cancer pain management by homecare nurses. Oncology nursing forum.
Villarreal Deborah, Restrepo Marcos I, Healy Jennifer, Howard Bonita, Tidwell Janet, Ross Jeanette, Hartronft Scotte, Jawad Marriyam, Sanchez-Reilly Sandra, Reed Kristin, Espinoza Sara E. (2011). A Model for Increasing Palliative Care in the Intensive Care Unit: Enhancing Interprofessional Consultation Rates and Communication. Journal of Pain and Symptom Management.
Walker J, Cassidy J, Sharpe M. (2009). The third symptom management research trial in oncology (SMaRT oncology-3): a randomised trial to determine the efficacy of adding a complex intervention for major depressive disorder (depression care for people with lung cancer) to usual care, compared to usual care alone in patients with lung cancer. Trials.
Woo J, Lo RSK, Lee J, Cheng JO, Lum CM, Hui E, Wong F, Yeung F, Or KK. (2009). Improving End-of-Life Care for Non-Cancer Patients in Hospitals: Description of a Continuous Quality Improvement Initiative. Journal of Nursing & Healthcare of Chronic Illnesses.

## Not a Study of Quality Improvement

(2009). A Nurse Delivered Management Programme for Depression in People With Cancer Reduces Depressive Symptoms Compared With Usual Care. Evidence-Based Mental Health.
(2006). Finding peace through hospice care. Johns Hopkins Med Lett Health After 50.
Adegbehingbe OO, Akinyoola AL, Ariyibi AL, Oginni LM. (2009). Direct integration of government funding and family support for musculoskeletal tumor care in a resource-constrained country. Oncology.
Ahmed Nisar, Ahmedzai Sam, Vora Vandana, Harrison Sophie, Paz Silvia. (2004). Supportive care for patients with gastrointestinal cancer. Cochrane Database of Systematic Reviews: Reviews.
Andersen BL, Farrar WB, Golden-Kreutz DM, Glaser R, Emery CF, Crespin TR, Shapiro CL, Carson WE. (2004). Psychological, behavioral, and immune changes after a psychological intervention: a clinical trial. J Clin Oncol.
Badger T, Segrin C, Meek P, Lopez AM, Bonham E, Sieger A. (2005). Telephone interpersonal counseling with women with breast cancer: symptom management and quality of life. Oncol Nurs Forum.
Baider L, Peretz T, Hadani PE, Koch U. (2001). Psychological intervention in cancer patients: a randomized study. General hospital psychiatry.
Bitzas Vasiliki, Calestagne Paula P, McVey Lynne, Lapointe Bernard. (2011). Encouraging patients and families to influence change on a palliative care unit: value of patient satisfaction surveys. Journal of Nursing Care Quality.
Bordeleau L, Szalai JP, Ennis M, Leszcz M, Speca M, Sela R, Doll R, Chochinov HM, Navarro M, Arnold A, Pritchard KI, Bezjak A, Llewellyn-Thomas HA, Sawka CA, Goodwin PJ. (2003). Quality of life in a randomized trial of group psychosocial support in metastatic breast cancer: overall effects of the intervention and an exploration of missing data. J Clin Oncol.
Brennan Caitlin W, Prince-Paul Maryjo, Wiencek Clareen A. (2011). Providing a “Good Death” for Oncology Patients During the Final Hours of Life in the Intensive Care Unit i. AACN Advanced Critical Care.
Brown RF, Butow PN, Sharrock MA, Henman M, Boyle F, Goldstein D, Tattersall MH. (2004). Education and role modelling for clinical decisions with female cancer patients. Health Expect.
Butler LD, Koopman C, Cordova MJ, Garlan RW, DiMiceli S, Spiegel D. (2003). Psychological distress and pain significantly increase before death in metastatic breast cancer patients. Psychosomatic medicine.
Cepeda MS, Chapman CR, Miranda N, Sanchez R, Rodriguez CH, Restrepo AE, Ferrer LM, Linares RA, Carr DB. (2008). Emotional disclosure through patient narrative may improve pain and well-being: results of a randomized controlled trial in patients with cancer pain. J Pain Symptom Manage.
Chan CL, Ho RT, Lee PW, Cheng JY, Leung PP, Foo W, Chow LW, Sham JS, Spiegel D. (2006). A randomized controlled trial of psychosocial interventions using the psychophysiological framework for Chinese breast cancer patients. Journal of psychosocial oncology.
Chan CW, Richardson A, Richardson J. (2011). Managing symptoms in patients with advanced lung cancer during radiotherapy: results of a psychoeducational randomized controlled trial. Journal of pain and symptom management.
Chan R, Webster J. (2010). End-of-life care pathways for improving outcomes in caring for the dying. Cochrane Database Syst Rev.
Chang PH, Lai YH, Shun SC, Lin LY, Chen ML, Yang Y, Tsai JC, Huang GS, Cheng SY. (2008). Effects of a Walking Intervention on Fatigue-Related Experiences of Hospitalized Acute Myelogenous Leukemia Patients Undergoing Chemotherapy: a Randomized Controlled Trial. Journal of Pain & Symptom Management.
Comley AL, DeMeyer E. (2001). Assessing patient satisfaction with pain management through a continuous quality improvement effort. J Pain Symptom Manage.
Cook AJ. (1998). Cognitive-behavioral pain management for elderly nursing home residents. The journals of gerontology. Series B, Psychological sciences and social sciences.
Cornbleet MA, Campbell P, Murray S, Stevenson M, Bond S. (2002). Patient-held records in cancer and palliative care: a randomized, prospective trialt. Palliat Med.
Coventry PA, Grande GE, Richards DA, Todd CJ. (2005). Prediction of appropriate timing of palliative care for older adults with non-malignant life-threatening disease: a systematic review. Age Ageing.
Cranston Josephine M, Crockett Alan, Currow David. (2008). Oxygen therapy for dyspnoea in adults. Cochrane Database of Systematic Reviews: Reviews.
Csaszar N, Ganju A, Mirnics ZS, Varga PP. (2009). Psychosocial issues in the cancer patient. Spine (Phila Pa 1976).
Currow DC, Abernethy AP, Shelby-James TM, Phillips PA. (2006). The impact of conducting a regional palliative care clinical study. Palliative medicine.
Danvers L, Freshwater D, Cheater F, Wilson A. (2003). Providing a Seamless Service for Children With Life-Limiting Illness: Experiences and Recommendations of Professional Staff at the Diana Princess of Wales Children's Community Service. Journal of Clinical Nursing.
Dewey ANN. (2010). Summaries of Nursing Rare-Related Systematic Reviews From the Cochrane Library: Psychosocial Interventions for Reducing Fatigue During Cancer Treatment in Adults. International Journal of Evidence-Based Healthcare.
Duggleby WD, Degner L, Williams A, Wright K, Cooper D, Popkin D, Holtslander L. (2007). Living with hope: initial evaluation of a psychosocial hope intervention for older palliative home care patients. J Pain Symptom Manage.
Erridge SC, Gaze MN, Price A, Kelly CG, Kerr GR, Cull A, MacDougall RH, Howard GC, Cowie VJ, Gregor A. (2005). Symptom control and quality of life in people with lung cancer: a randomised trial of two palliative radiotherapy fractionation schedules. Clinical oncology (Royal College of Radiologists (Great Britain)).
Friedrichsdorf SJ. (2010). Pain management in children with advanced cancer and during end-of-life care. Pediatr Hematol Oncol.
Gillick MR. (2004). Adapting advance medical planning for the nursing home. J Palliat Med.
Given B, Given CW, Sikorskii A, Jeon S, Sherwood P, Rahbar M. (2006). The Impact of Providing Symptom Management Assistance on Caregiver Reaction: Results of a Randomized Trial. Journal of Pain & Symptom Management.
Given C, Given B, Rahbar M, Jeon S, McCorkle R, Cimprich B, Galecki A, Kozachik S, Devoss D, Brady A, Fisher-Malloy MJ, Courtney K, Bowie E. (2004). Does a symptom management intervention affect depression among cancer patients: results from a clinical trial. Psychooncology.
Gysels M, Richardson A, Higginson IJ. (2004). Communication training for health professionals who care for patients with cancer: a systematic review of effectiveness. Support Care Cancer.
Haber J. (2004). Review: Existing Evidence Does Not Support a Survival Benefit for Women With Metastatic Breast Cancer Who Participate in Group Psychological Interventions Compared With Usual Care. Evidence-Based Nursing.
Hall S, Chochinov H, Harding R, Murray S, Richardson A, Higginson IJ. (2009). A Phase II randomised controlled trial assessing the feasibility, acceptability and potential effectiveness of dignity therapy for older people in care homes: study protocol. BMC Geriatr.
Hanser SB, Bauer-Wu S, Kubicek L, Healey M, Manola J, Hernandez M, Bunnell C. (2006). Effects of a music therapy intervention on quality of life and distress in women with metastatic breast cancer. J Soc Integr Oncol.
Hersch J, Juraskova I, Price M, Mullan B. (2009). Psychosocial interventions and quality of life in gynaecological cancer patients: a systematic review. Psychooncology.
Hill TE, Ginsburg M, Citko J, Cadogan M. (2005). Improving End-of-Life Care in Nursing Facilities: the Community State Partnership to Improve End-of-Life Care -California. Journal of Palliative Medicine.
Hoffmann W, Munzinger H, Horstkotte E, Greiser E. (2004). A population-based evaluation of an intervention to improve advanced stage cancer pain management. J Pain Symptom Manage.
Houts AC, Lipinski D, Olsen JP, Baldwin S, Hasan M. (2010). Use of the Patient Care Monitor to screen for depression in adult cancer patients interviewed with the structured clinical interview for DSM-IV. Psychooncology.
Husebo BS, Ballard C, Aarsland D. (2011). Pain treatment of agitation in patients with dementia: a systematic review. Int J Geriatr Psychiatry.
Jack B, Boland A, Dickson R, Stevenson J, McLeod C. (2010). Best supportive care in lung cancer trials is inadequately described: a systematic review. Eur J Cancer Care (Engl).
Johansson B, Holmberg L, Berglund G, Brandberg Y, Hellbom M, Persson C, Glimelius B, Sjoden PO. (2001). Reduced utilisation of specialist care among elderly cancer patients: a randomised study of a primary healthcare intervention. Eur J Cancer.
Jones KR, Fink R, Vojir C, Pepper G, Hutt E, Clark L, Scott J, Martinez R, Vincent D, Mellis BK. (2004). Translation research in long-term care: improving pain management in nursing homes. Worldviews Evid Based Nurs.
Kaasalainen Sharon, Brazil Kevin, Coker Esther, Ploeg Jenny, Martin-Misener Ruth, Donald Faith, Dicenso Alba, Hadjistavropoulos Thomas, Dolovich Lisa, Papaioannou Alexandra, Emili Anna, Burns TIM. (2010). An Action-Based Approach to Improving Pain Management in Long-Term Care. Canadian Journal on Aging.
Kang KA, Shim JS, Jeon DG, Koh MS. (2009). J Korean Acad Nurs.
Kirchhoff KT, Hammes BJ, Kehl KA, Briggs LA, Brown RL. (2010). Effect of a disease-specific planning intervention on surrogate understanding of patient goals for future medical treatment. J Am Geriatr Soc.
Kissane DW, McKenzie M, Bloch S, Moskowitz C, McKenzie DP, O'Neill I. (2006). Family focused grief therapy: a randomized, controlled trial in palliative care and bereavement. Am J Psychiatry.
Klosky JL, Tyc VL, Srivastava DK, Tong X, Kronenberg M, Booker ZJ, de Armendi AJ, Merchant TE. (2004). Brief report: Evaluation of an interactive intervention designed to reduce pediatric distress during radiation therapy procedures. J Pediatr Psychol.
Kolarik RC, Arnold RM, Fischer GS, Hanusa BH. (2002). Advance care planning. J Gen Intern Med.
Kristeller JL, Rhodes M, Cripe LD, Sheets V. (2005). Oncologist Assisted Spiritual Intervention Study (OASIS): patient acceptability and initial evidence of effects. Int J Psychiatry Med.
Kurtz ME, Kurtz JC, Given CW, Given B. (2005). A randomized, controlled trial of a patientcaregiver symptom control intervention: effects on depressive symptomatology of caregivers of cancer patients. J Pain Symptom Manage.
Kutner JS, Bryant LL, Beaty BL, Fairclough DL. (2006). Symptom Distress and Quality-of-Life Assessment at the End of Life: the Role of Proxy Response. Journal of Pain & Symptom Management.
Kutner JS, Metcalfe T, Vu KO, Fink R, Nelson-Marten P, Armstrong JD, Seligman PA. (2004). Implementation of an ad hoc hospital-based palliative care consult service. J Pain Symptom Manage.
Kutzen H. (2001). Advanced HIV care planning: how to begin “the” conversation. HIV Clin.
Laycock W. (2011). Think about it: a prompt to discuss end of life choices. Nurs Times.
Lecouturier J, Crack L, Mannix K, Hall RH, Bond S. (2002). Evaluation of a patient-held record for patients with cancer. Eur J Cancer Care (Engl).
Lee M, Booth S. (2008). The pace program and end-of-life care. Providence ElderPlace in Porland, Ore., develops unique approach for enrolled participants. Health Prog.
Leonard W. (2000). Summary of Task Forces I, II, and III, and report of Task Force IV Education & Implementation. Clin Cardiol.
Leone AF, Standoli F, Hirth V. (2009). Implementing a pain management program in a long-term care facility using a quality improvement approach. J Am Med Dir Assoc.
Lin CC, Chou PL, Wu SL, Chang YC, Lai YL. (2006). Long-term effectiveness of a patient and family pain education program on overcoming barriers to management of cancer pain. Pain.
Lincoln A. (2008). Improving the conditions of confinement. End-of-life care in prison. Pharos Alpha Omega Alpha Honor Med Soc.
Liu LN, Li CY, Tang ST, Huang CS, Chiou AF. (2006). Role of continuing supportive cares in increasing social support and reducing perceived uncertainty among women with newly diagnosed breast cancer in Taiwan. Cancer Nurs.
Lorenz KA. (2008). Progress in quality-of-care research and hope for supportive cancer care. J Clin Oncol.
Maex E, De Valck C. (2004). Taking care of the terminally ill cancer patient: the communication compass--a model for communication in oncology. Ann Oncol.
Maguire P, Pitceathly C. (2003). Improving the psychological care of cancer patients and their relatives. The role of specialist nurses. J Psychosom Res.
Mallick I, Sharma SC, Behera D, Ghoshal S, Oinam AS. (2006). Optimization of dose and fractionation of endobronchial brachytherapy with or without external radiation in the palliative management of non-small cell lung cancer: a prospective randomized study. Journal of cancer research and therapeutics.
Manne SL, Rubin S, Edelson M, Rosenblum N, Bergman C, Hernandez E, Carlson J, Rocereto T, Winkel G. (2007). Coping and communication-enhancing intervention versus supportive counseling for women diagnosed with gynecological cancers. J Consult Clin Psychol.
Martin-Carrasco M, Martin MF, Valero CP, Millan PR, Garcia CI, Montalban SR, Vazquez ALG, Piris SP, Vilanova MB. (2009). Effectiveness of a psychoeducation intervention program in the reduction of caregiver burden in Alzheimer's Disease patients' caregivers. International Journal of Geriatric Psychiatry.
McCann L, Maguire R, Miller M, Kearney N. (2009). Patients' perceptions and experiences of using a mobile phone-based advanced symptom management system (ASyMS) to monitor and manage chemotherapy related toxicity. Eur J Cancer Care (Engl).
Mcclive Kimberly Pender. (2004). The Effects of an Advanced Illness Care Coordination Program on Patient Satisfaction With Health Care Through Improved Patient-Provider Communication. Dissertation Abstracts International: Section B: the Sciences and Engineering.
McGarvey EL, Leon-Verdin M, Baum LD, Bloomfield K, Brenin DR, Koopman C, Acton S, Clark B, Parker BE. (2010). An evaluation of a computer-imaging program to prepare women for chemotherapy-related alopecia. Psychooncology.
McQuay Henry J, Collins Sally, Carroll Dawn, Moore R. Andrew. (1999). Radiotherapy for the palliation of painful bone metastases. Cochrane Database of Systematic Reviews: Reviews.
Miller DK, Chibnall JT, Videen SD, Duckro PN. (2005). Supportive-affective group experience for persons with life-threatening illness: reducing spiritual, psychological, and death-related distress in dying patients. J Palliat Med.
Mishra S, Bhatnagar S, Singh M, Gupta D, Jain R, Chauhan H, Goyal GN. (2009). Pediatric cancer pain management at a regional cancer center: implementation of WHO Analgesic Ladder. Middle East journal of anesthesiology.
Mitchell CG. (2003). Mood Disturbance in Oncology Patients With Metastatic Bone Pain in a Self-Care Nursing Intervention.
Monroe Todd Bryant. (2010). Pain Management in Nursing Home Residents With Cancer and Dementia With and Without Hospice Services. Dissertation Abstracts International: Section B: the Sciences and Engineering.
Murray MA, Stacey D, Wilson KG, O'Connor AM. (2010). Skills training to support patients considering place of end-of-life care: a randomized control trial. Journal of palliative care.
Naylor MD, Brooten D, Campbell R, Jacobsen BS, Mezey MD, Pauly MV, Schwartz JS. (1999). Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA: the journal of the American Medical Association.
Nightingale E, Kristjanson LJ, Toye C. (2003). Evaluating the Navigate Care Model: clinical palliative care pathways based on anticipated care outcomes. Int J Palliat Nurs.
Norton SA, Hogan LA, Holloway RG, Temkin-Greener H, Buckley MJ, Quill TE. (2007). Proactive palliative care in the medical intensive care unit: effects on length of stay for selected high-risk patients. Crit Care Med.
O'Brien MA, Whelan TJ, Villasis-Keever M, Gafni A, Charles C, Roberts R, Schiff S, Cai W. (2009). Are cancer-related decision aids effective? A systematic review and meta-analysis. J Clin Oncol.
Oleske DM, Hauck WW. (1988). A population-based evaluation of the impact of interventions for improving care to cancer patients in the home setting. Home Health Care Services Quarterly.
O'Mahony S, McHenry J, Blank AE, Snow D, Eti Karakas S, Santoro G, Selwyn P, Kvetan V. (2010). Preliminary report of the integration of a palliative care team into an intensive care unit. Palliat Med.
Perry E, Swartz J, Brown S, Smith D, Kelly G, Swartz R. (2005). Peer mentoring: a culturally sensitive approach to end-of-life planning for long-term dialysis patients. Am J Kidney Dis.
Posthauer ME. (2007). The role of nutritional therapy in palliative care. Adv Skin Wound Care.
Rao AV, Hsieh F, Feussner JR, Cohen HJ. (2005). Geriatric evaluation and management units in the care of the frail elderly cancer patient. J Gerontol A Biol Sci Med Sci.
Ravasco P, Monteiro Grillo I, Camilo M. (2007). Cancer wasting and quality of life react to early individualized nutritional counselling!. Clinical Nutrition.
Resnick B, Quinn C, Baxter S. (2004). Testing the feasibility of implementation of clinical practice guidelines in long-term care facilities. J Am Med Dir Assoc.
Rodin G, Lloyd N, Katz M, Green E, Mackay JA, Wong RK. (2007). The treatment of depression in cancer patients: a systematic review. Support Care Cancer.
Rodin G, Zimmermann C, Mayer C, Howell D, Katz M, Sussman J, Mackay JA, Brouwers M. (2009). Clinician-patient communication: evidence-based recommendations to guide practice in cancer. Curr Oncol.
Sahler OJ, Fairclough DL, Phipps S, Mulhern RK, Dolgin MJ, Noll RB, Katz ER, Varni JW, Copeland DR, Butler RW. (2005). Using problem-solving skills training to reduce negative affectivity in mothers of children with newly diagnosed cancer: report of a multisite randomized trial. J Consult Clin Psychol.
Schenker Y. (2009). Nurse-Led Palliative Care Improves Quality of Life and Mood of Cancer Patients. Journal of Clinical Outcomes Management.
Schofield P, Carey M, Love A, Nehill C, Wein S. (2006). ‘Would you like to talk about your future treatment options’? Discussing the transition from curative cancer treatment to palliative care. Palliat Med.
Scott JT, Harmsen M, Prictor MJ, Sowden AJ, Watt I. (2003). Interventions for improving communication with children and adolescents about their cancer. Cochrane Database Syst Rev.
Shalowitz DI, Garrett-Mayer E, Wendler D. (2006). The accuracy of surrogate decision makers: a systematic review. Arch Intern Med.
Shell JA. (2002). Evidence-based practice for symptom management in adults with cancer: sexual dysfunction. Oncol Nurs Forum.
Silliman RA, McGarvey ST, Raymond PM, Fretwell MD. (1990). The Senior Care Study. Does inpatient interdisciplinary geriatric assessment help the family caregivers of acutely ill older patients?. Journal of the American Geriatrics Society.
Smith MC, Kemp J, Hemphill L, Vojir CP. (2002). Outcomes of therapeutic massage for hospitalized cancer patients. Journal of nursing scholarship: an official publication of Sigma Theta Tau International Honor Society of Nursing Sigma Theta Tau.
Steinhauser KE, Alexander SC, Byock IR, George LK, Olsen MK, Tulsky JA. (2008). Do preparation and life completion discussions improve functioning and quality of life in seriously ill patients? Pilot randomized control trial. J Palliat Med.
Stenberg U, Ruland CM, Miaskowski C. (2010). Review of the literature on the effects of caring for a patient with cancer. Psychooncology.
Sudore RS, Mayer G. (2006). End-of-life decisions made easier. Provider.
Tattersall MH, Gattellari M, Voigt K, Butow PN. (2002). When the treatment goal is not cure: are patients informed adequately?. Support Care Cancer.
Treece PD, Engelberg RA, Crowley L, Chan JD, Rubenfeld GD, Steinberg KP, Curtis JR. (2004). Evaluation of a standardized order form for the withdrawal of life support in the intensive care unit. Crit Care Med.
Twaddle ML, Sheehan M, Romer AL. (2003). Filling the gaps in service for patients who need supportive care. J Palliat Med.
Uitterhoeve RJ, Vernooy M, Litjens M, Potting K, Bensing J, De Mulder P, van Achterberg T. (2004). Psychosocial interventions for patients with advanced cancer a systematic review of the literature. Br J Cancer.
Vandenberg EV, Tvrdik A, Keller BK. (2005). Use of the quality improvement process in assessing end-of-life care in the nursing home. J Am Med Dir Assoc.
Vodermaier A, Linden W, Siu C. (2009). Screening for emotional distress in cancer patients: a systematic review of assessment instruments. J Natl Cancer Inst.
Vogel L. (2011). Tools help patients tackle tough choices for end-of-life care. CMAJ.
Wong FK, Chow SK, Chan TM. (2010). Evaluation of a nurse-led disease management programme for chronic kidney disease: a randomized controlled trial. International journal of nursing studies.
Young J, Harrison J, Solomon M, Butow P, Dennis R, Robson D, Auld S. (2010). Development and feasibility assessment of telephone-delivered supportive care to improve outcomes for patients with colorectal cancer: pilot study of the CONNECT intervention. Support Care Cancer.

## Not an Included Study Design

(2004). Best practices guide statewide QI project. Healthcare Benchmarks Qual Improv.
(2006). Doctor-Patient Communication Is Critical to How Parents View the Quality of End-of-Life Care for Children With Cancer. Ahrq Research Activities.
Abbo ED, Volandes AE. (2008). A forced choice: the value of requiring advance directives. J Clin Ethics.
Ahmed Nisar, Ahmedzai Sam, Vora Vandana, Harrison Sophie, Paz Silvia. (2004). Supportive care for patients with gastrointestinal cancer. Cochrane Database of Systematic Reviews: Reviews.
Bucher JA, Loscalzo M, Zabora J, Houts PS, Hooker C, BrintzenhofeSzoc K. (2001). Problem-solving cancer care education for patients and caregivers. Cancer Pract.
Butler LD, Koopman C, Cordova MJ, Garlan RW, DiMiceli S, Spiegel D. (2003). Psychological distress and pain significantly increase before death in metastatic breast cancer patients. Psychosomatic medicine.
Casarett D, Kapo J, Caplan A. (2005). Appropriate use of artificial nutrition and hydration--fundamental principles and recommendations. N Engl J Med.
Chung SK, Ahn MJ, Yoo JY, Choi M, Hyang N, Woo SR, Kim SS, Kim SA, Oh EG. (2011). Implementation of best practice for chemotherapy-induced nausea and vomiting in an acute care setting. Int J Evid Based Healthc.
Clark Paul G. (2008). The Relationship Between Psychological Distress and Health Efficacy in People With Cancer in an Acute Inpatient Care Setting: an Intervention Study. Dissertation Abstracts International Section a: Humanities and Social Sciences.
Daly BJ. (2000). Organizational change and delivery of multidisciplinary palliative care. Respir Care.
Danvers L, Freshwater D, Cheater F, Wilson A. (2003). Providing a Seamless Service for Children With Life-Limiting Illness: Experiences and Recommendations of Professional Staff at the Diana Princess of Wales Children's Community Service. Journal of Clinical Nursing.
Dewey ANN. (2010). Summaries of Nursing Rare-Related Systematic Reviews From the Cochrane Library: Psychosocial Interventions for Reducing Fatigue During Cancer Treatment in Adults. International Journal of Evidence-Based Healthcare.
Di Leo Silvia, Beccaro Monica, Finelli Stefania, Borreani Claudia, Costantini Massimo. (2011). Expectations about and impact of the Liverpool Care Pathway for the dying patient in an Italian hospital. Palliative Medicine.
Dulko D. (2007). Implementation of National Pain Guidelines by Acute Care Oncology Nurse Practitioners Using an Audit and Feedback Strategy.
Fisher Susan E. (2007). A Pain Assessment and Communication Training Intervention to Improve Detection of Behavioral Pain Cues and Pain Management Communication Among Direct-Care Staff in the Nursing Home. Dissertation Abstracts International: Section B: the Sciences and Engineering.
Forchuk CA. (2009). Nurse-Delivered Intervention Was Effective for Depression in Patients With Cancer. Evidence-Based Nursing.
Ford Pitorak E, Beckham Armour M, Sivec HD. (2003). Project safe conduct integrates palliative goals into comprehensive cancer care. J Palliat Med.
Friedrichsdorf SJ. (2010). Pain management in children with advanced cancer and during end-of-life care. Pediatr Hematol Oncol.
Gaertner Jan, Wuerstlein Rachel, Klein Ursula, Scheicht Dennis, Frechen Sebastian, Wolf J++rgen, Hellmich Martin, Mallmann Peter, Harbeck Nadia, Voltz Raymond. (2011). Integrating Palliative Medicine into Comprehensive Breast Cancer Therapy a Pilot Project. Breast Care.
Glajchen M, Lawson R, Homel P, Desandre P, Todd KH. (2011). A rapid two-stage screening protocol for palliative care in the emergency department: a quality improvement initiative. J Pain Symptom Manage.
Gysels M, Richardson A, Higginson IJ. (2004). Communication training for health professionals who care for patients with cancer: a systematic review of effectiveness. Support Care Cancer.
Haber J. (2004). Review: Existing Evidence Does Not Support a Survival Benefit for Women With Metastatic Breast Cancer Who Participate in Group Psychological Interventions Compared With Usual Care. Evidence-Based Nursing.
Hall S, Edmonds P, Harding R, Chochinov H, Higginson IJ. (2009). Assessing the feasibility, acceptability and potential effectiveness of Dignity Therapy for people with advanced cancer referred to a hospital-based palliative care team: Study protocol. BMC Palliat Care.
Harris D, Hillier LM, Keat N. (2007). Sustainable practice improvements: impact of the Comprehensive Advanced Palliative Care Education (CAPCE) program. J Palliat Care.
Holley S, Borger D. (2001). Energy for living with cancer: preliminary findings of a cancer rehabilitation group intervention study. Oncol Nurs Forum.
Hudson P, Thomas T, Quinn K, Cockayne M, Braithwaite M. (2009). Teaching family carers about home-based palliative care: final results from a group education program. J Pain Symptom Manage.
Jones K. (2006). Effective pain management: lessons from a nursing home research study. J Healthc Qual.
Kane RL, Mach JR. (2007). Improving Health Care for Assisted Living Residents. Gerontologist.
Katz MR, Irish JC, Devins GM. (2004). Development and pilot testing of a psychoeducational intervention for oral cancer patients. Psychooncology.
Kaufer M, Murphy P, Barker K, Mosenthal A. (2008). Family satisfaction following the death of a loved one in an inner city MICU. Am J Hosp Palliat Care.
Kutzen H. (2001). Advanced HIV care planning: how to begin “the” conversation. HIV Clin.
Lee M, Booth S. (2008). The pace program and end-of-life care. Providence ElderPlace in Porland, Ore., develops unique approach for enrolled participants. Health Prog.
Leonard W. (2000). Summary of Task Forces I, II, and III, and report of Task Force IV Education & Implementation. Clin Cardiol.
Leone AF, Standoli F, Hirth V. (2009). Implementing a pain management program in a long-term care facility using a quality improvement approach. J Am Med Dir Assoc.
Lin CC, Chou PL, Wu SL, Chang YC, Lai YL. (2006). Long-term effectiveness of a patient and family pain education program on overcoming barriers to management of cancer pain. Pain.
Lincoln A. (2008). Improving the conditions of confinement. End-of-life care in prison. Pharos Alpha Omega Alpha Honor Med Soc.
Loke Song-Seng, Rau Kung-Ming, Huang Chih-Fang. (2011). Impact of Combined Hospice Care on Terminal Cancer Patients. Journal of Palliative Medicine.
Lokk J. (2007). Lakartidningen.
London MR, McSkimming S, Drew N, Quinn C, Carney B. (2005). Evaluation of a Comprehensive, Adaptable, LifeAffirming, Longitudinal (CALL) palliative care project. J Palliat Med.
Lorenz KA. (2008). Progress in quality-of-care research and hope for supportive cancer care. J Clin Oncol.
Lynn J, Nolan K, Kabcenell A, Weissman D, Milne C, Berwick DM. (2002). Reforming care for persons near the end of life: the promise of quality improvement. Ann Intern Med.
Lynn J, Schall MW, Milne C, Nolan KM, Kabcenell A. (2000). Quality improvements in end of life care: insights from two collaboratives. Jt Comm J Qual Improv.
Maex E, De Valck C. (2004). Taking care of the terminally ill cancer patient: the communication compass--a model for communication in oncology. Ann Oncol.
Martin WE, Miller SC, Welch LC, Burrill J. (2007). Improving access to hospice: the Physician Feedback and Reminders to Improve Access to Hospice (PFRIAH) study. Med Health R I.
Mcclive Kimberly Pender. (2004). The Effects of an Advanced Illness Care Coordination Program on Patient Satisfaction With Health Care Through Improved Patient-Provider Communication. Dissertation Abstracts International: Section B: the Sciences and Engineering.
Meyers FJ, Linder J. (2003). Simultaneous care: disease treatment and palliative care throughout illness. J Clin Oncol.
Mishra S, Bhatnagar S, Singh M, Gupta D, Jain R, Chauhan H, Goyal GN. (2009). Pediatric cancer pain management at a regional cancer center: implementation of WHO Analgesic Ladder. Middle East journal of anesthesiology.
Mitchell CG. (2003). Mood Disturbance in Oncology Patients With Metastatic Bone Pain in a Self-Care Nursing Intervention.
Moback Berit, Gerrard Ruth, Minton Ollie, Campbell Janet, Taylor Lucie, Stone Patrick Charles. (2011). Evaluating a fast-track discharge service for patients wishing to die at home. International Journal of Palliative Nursing.
Monroe Todd Bryant. (2010). Pain Management in Nursing Home Residents With Cancer and Dementia With and Without Hospice Services. Dissertation Abstracts International: Section B: the Sciences and Engineering.
Mularski RA, Curtis JR, Billings JA, Burt R, Byock I, Fuhrman C, Mosenthal AC, Medina J, Ray DE, Rubenfeld GD, Schneiderman LJ, Treece PD, Truog RD, Levy MM. (2006). Proposed quality measures for palliative care in the critically ill: a consensus from the Robert Wood Johnson Foundation Critical Care Workgroup. Crit Care Med.
Nightingale E, Kristjanson LJ, Toye C. (2003). Evaluating the Navigate Care Model: clinical palliative care pathways based on anticipated care outcomes. Int J Palliat Nurs.
Northouse LL, Walker J, Schafenacker A, Mood D, Mellon S, Galvin E, Harden J, Freeman-Gibb L. (2002). A family-based program of care for women with recurrent breast cancer and their family members. Oncol Nurs Forum.
Oldenmenger WH, Sillevis Smitt PA, van Dooren S, Stoter G, van der Rijt CC. (2009). A systematic review on barriers hindering adequate cancer pain management and interventions to reduce them: a critical appraisal (Structured abstract). European Journal of Cancer.
Oliver DP, Bickel-Swenson D, Zweig S, Kruse R, Mehr D. (2009). Experience with implementation of a quality improvement project for the care of nursing home residents. J Nurs Care Qual.
Powis J, Etchells E, Martin DK, MacRae SK, Singer PA. (2004). Can a “good death” be made better?: A preliminary evaluation of a patient-centred quality improvement strategy for severely ill in-patients. BMC Palliat Care.
Puntillo KA, Mcadam JL. (2006). Communication Between Physicians and Nurses as a Target for Improving End-of-Life Care in the Intensive Care Unit: Challenges and Opportunities for Moving Forward. Critical Care Medicine.
Quill TE. (2004). Dying and decision making--evolution of end-of-life options. N Engl J Med.
Resultan E. (2003). Improving the quality of care for terminally ill children. Healthplan.
Rodin G, Zimmermann C, Mayer C, Howell D, Katz M, Sussman J, Mackay JA, Brouwers M. (2009). Clinician-patient communication: evidence-based recommendations to guide practice in cancer. Curr Oncol.
Russell PB, Aveyard SC, Oxenham DR. (2006). An assessment of methods used to evaluate the adequacy of cancer pain management. J Pain Symptom Manage.
Sarna L. (1998). Effectiveness of structured nursing assessment of symptom distress in advanced lung cancer. Oncol Nurs Forum.
Schenker Y. (2009). Nurse-Led Palliative Care Improves Quality of Life and Mood of Cancer Patients. Journal of Clinical Outcomes Management.
Schneider NM. (2004). Managing congestive heart failure using home telehealth. Home Healthc Nurse.
Semple CJ, McGowan B. (2002). Need for appropriate written information for patients, with particular reference to head and neck cancer. J Clin Nurs.
Shirahama M, Tanba K, Yoshida K, Nagata M, Ikeda Y. (2007). Nippon Naika Gakkai Zasshi.
Shojania KG, Duncan BW, McDonald KM, Wachter RM, Markowitz AJ. (2001). Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ).
Silveira MJ, Given CW, Cease KB, Sikorskii A, Given B, Northouse LL, Piette JD. (2011). Cancer CarePartners: Improving patients' symptom management by engaging informal caregivers. BMC Palliat Care.
Sitzia J, Cotterell P, Richardson A. (2006). Interprofessional collaboration with service users in the development of cancer services: the Cancer Partnership Project. J Interprof Care.
Sr Marie Ruegg, Schirm V, Boyce B. (2004). Making “caring connections”. A new program enhances end-of-life care in a retirement community in Ohio. Health Prog.
Stevenson KM, Dahl JL, Berry PH, Beck SL, Griffie J. (2006). Institutionalizing effective pain management practices: practice change programs to improve the quality of pain management in small health care organizations. J Pain Symptom Manage.
Taplin SH, Rodgers AB. (2010). Toward improving the quality of cancer care: addressing the interfaces of primary and oncology-related subspecialty care. J Natl Cancer Inst Monogr.
Taplin SH, Clauser S, Rodgers AB, Breslau E, Rayson D. (2010). Interfaces across the cancer continuum offer opportunities to improve the process of care. J Natl Cancer Inst Monogr.
Tattersall MH, Gattellari M, Voigt K, Butow PN. (2002). When the treatment goal is not cure: are patients informed adequately?. Support Care Cancer.
Valgus J, Jarr S, Schwartz R, Rice M, Bernard SA. (2010). Pharmacist-led, interdisciplinary model for delivery of supportive care in the ambulatory cancer clinic setting. J Oncol Pract.
Vandenberg EV, Tvrdik A, Keller BK. (2005). Use of the quality improvement process in assessing end-of-life care in the nursing home. J Am Med Dir Assoc.
Velikova G, Brown JM, Smith AB, Selby PJ. (2002). Computer-based quality of life questionnaires may contribute to doctor-patient interactions in oncology. Br J Cancer.
Velji K.
Volker DL, Kahn D, Penticuff JH. (2004). Patient control and end-of-life care part II: the advanced practice nurse perspective. Oncol Nurs Forum.
Walker J, Cassidy J, Sharpe M. (2009). The third symptom management research trial in oncology (SMaRT oncology-3): a randomised trial to determine the efficacy of adding a complex intervention for major depressive disorder (depression care for people with lung cancer) to usual care, compared to usual care alone in patients with lung cancer. Trials.
Wilson S, Wahler R, Brown J, Doloresco F, Monte SV. (2010). Impact of Pharmacist Intervention on Clinical Outcomes in the Palliative Care Setting. Am J Hosp Palliat Care.
Wilson Shelley, Wahler Robert, Brown Jack, Doloresco Fred, Monte Scott V. (2011). Impact of Pharmacist Intervention on Clinical Outcomes in the Palliative Care Setting. American Journal of Hospice & Palliative Medicine.
Woo J, Lo RSK, Lee J, Cheng JO, Lum CM, Hui E, Wong F, Yeung F, Or KK. (2009). Improving End-of-Life Care for Non-Cancer Patients in Hospitals: Description of a Continuous Quality Improvement Initiative. Journal of Nursing & Healthcare of Chronic Illnesses.

## Published Before 2000

Dufault MA, Willey-Lessne C. J Nurs Care Qual.
Sarna L. (1998). Effectiveness of structured nursing assessment of symptom distress in advanced lung cancer. Oncol Nurs Forum.

## Other

Harding R, Higginson IJ. (2003). What is the best way to help caregivers in cancer and palliative care? A systematic literature review of interventions and their effectiveness. Palliat Med.
McQuay Henry J, Collins Sally, Carroll Dawn, Moore R. Andrew. (1999). Radiotherapy for the palliation of painful bone metastases. Cochrane Database of Systematic Reviews: Reviews.
Oldenmenger WH, Sillevis Smitt PA, van Dooren S, Stoter G, van der Rijt CC. (2009). A systematic review on barriers hindering adequate cancer pain management and interventions to reduce them: a critical appraisal (Structured abstract). European Journal of Cancer.